# References and included studies

1 Practice parameters for the indications for polysomnography and related procedures. Polysomnography Task Force, American Sleep Disorders Association Standards of Practice Committee. Sleep. 1997;20(6):406-422. [pmid: 9302725].
2 Marin JM, Carrizo SJ, Vicente E, Agusti AG. Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lancet. 2005;365(9464):1046-1053. [pmid: 15781100].
3 Yaggi HK, Concato J, Kernan WN, et al. Obstructive sleep apnea as a risk factor for stroke and death. N Engl J Med. 2005;353(19):2034-2041. [pmid: 16282178].
4 Young T, Palta M, Dempsey J, et al. The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med. 1993;328(17):1230-1235. [pmid: 8464434].
5 Shahar E, Whitney CW, Redline S, et al. Sleep-disordered breathing and cardiovascular disease: cross-sectional results of the Sleep Heart Health Study. Am J Respir Crit Care Med. 2001;163(1):19-25. [pmid: 11208620].
6 Nieto FJ, Young TB, Lind BK, et al. Association of sleep-disordered breathing, sleep apnea, and hypertension in a large community-based study. Sleep Heart Health Study. JAMA. 2000;283(14):1829-1836. [pmid: 10770144].
7 Peppard PE, Young T, Palta M, Skatrud J. Prospective study of the association between sleep-disordered breathing and hypertension. N Engl J Med. 2000;342(19):1378-1384. [pmid: 10805822].
8 Young T, Peppard P, Palta M, et al. Population-based study of sleep-disordered breathing as a risk factor for hypertension. Arch Intern Med. 1997;157(15):1746-1752. [pmid: 9250236].
9 Babu AR, Herdegen J, Fogelfeld L, Shott S, Mazzone T. Type 2 diabetes, glycemic control, and continuous positive airway pressure in obstructive sleep apnea. Arch Intern Med. 2005;165(4):447-452. [pmid: 15738376].
10 Gruber A, Horwood F, Sithole J, Ali NJ, Idris I. Obstructive sleep apnoea is independently associated with the metabolic syndrome but not insulin resistance state. Cardiovasc Diabetol. 2006;5:22. [pmid: 17078884].
11 Howard ME, Desai AV, Grunstein RR, et al. Sleepiness, sleep-disordered breathing, and accident risk factors in commercial vehicle drivers. Am J Respir Crit Care Med. 2004;170(9):1014-1021. [pmid: 15317672].
12 Teran-Santos J, Jimenez-Gomez A, Cordero-Guevara J. The association between sleep apnea and the risk of traffic accidents. Cooperative Group Burgos-Santander. N Engl J Med. 1999;340(11):847-851. [pmid: 10080847].
13 Flemons WW, Littner MR, Rowley JA, et al. Home diagnosis of sleep apnea: a systematic review of the literature. An evidence review cosponsored by the American Academy of Sleep Medicine, the American College of Chest Physicians, and the American Thoracic Society. Chest. 2003;124(4):1543-1579. [pmid: 14555592].
14 Young T, Peppard PE, Taheri S. Excess weight and sleep-disordered breathing. J Appl Physiol. 2005;99(4):1592-1599. [pmid: 16160020].
15 Young T, Shahar E, Nieto FJ, et al. Predictors of sleep-disordered breathing in community-dwelling adults: the Sleep Heart Health Study. Arch Intern Med. 2002;162(8):893-900. [pmid: 11966340].
16 Ancoli-Israel S, Kripke DF, Klauber MR, et al. Sleep-disordered breathing in community-dwelling elderly. Sleep. 1991;14(6):486-495. [pmid: 1798880].
17 Bixler EO, Vgontzas AN, Ten HT, Tyson K, Kales A. Effects of age on sleep apnea in men: I. Prevalence and severity. Am J Respir Crit Care Med. 1998;157(1):144-148. [pmid: 9445292].
18 Bixler EO, Vgontzas AN, Lin HM, et al. Prevalence of sleep-disordered breathing in women: effects of gender. Am J Respir Crit Care Med. 2001;163(3 Pt 1):608-613. [pmid: 11254512].
19 Duran J, Esnaola S, Rubio R, Iztueta A. Obstructive sleep apnea-hypopnea and related clinical features in a population-based sample of subjects aged 30 to 70 yr. Am J Respir Crit Care Med. 2001;163(3 Pt 1):685-689. [pmid: 11254524].
20 Young T, Peppard PE, Gottlieb DJ. Epidemiology of obstructive sleep apnea: a population health perspective. Am J Respir Crit Care Med. 2002;165(9):1217-1239. [pmid: 11991871].
21 Ferber R, Millman R, Coppola M, et al. Portable recording in the assessment of obstructive sleep apnea. ASDA standards of practice. Sleep. 1994;17(4):378-392. [pmid: 7973323].
22 Lux L, Boehlecke B, Lohr KN. Effects of portable monitoring devices for diagnosing obstructive sleep apnea: Update of a systematic review. 290-20-0016. 2006. Agency for Healthcare Research and Quality.
23 Ayappa I, Norman RG, Krieger AC, et al. Non-Invasive detection of respiratory effort-related arousals (REras) by a nasal cannula/pressure transducer system. Sleep. 2000;23(6):763-771. [pmid: 11007443].
24 Masa JF, Corral J, Martin MJ, et al. Assessment of thoracoabdominal bands to detect respiratory effort-related arousal. European Respiratory Journal. 2003;22(4):661-667. [pmid: 14582921].
25 Rechtcshaffen A, Kales A. A manual of standardized techniques and scoring system for sleep staging of human subjects. Los Angeles. Brain Information Service and Brain Research Institute. 1968.
26 Fleury B, Rakotonanahary D, Hausser-Hauw C, Lebeau B, Guilleminault C. A laboratory validation study of the diagnostic mode of the Autoset system for sleep-related respiratory disorders.[erratum appears in Sleep 1996 Sep;19(7):601]. Sleep. 1996;19(6):502-505. [pmid: 8865509].
27 Pepin JL, Levy P, Lepaulle B, Brambilla C, Guilleminault C. Does oximetry contribute to the detection of apneic events? Mathematical processing of the SaO2 signal. Chest. 1991;99(5):1151-1157. [pmid: 2019170].
28 Esnaola S, Duran J, Infante-Rivard C, Rubio R, Fernandez A. Diagnostic accuracy of a portable recording device (MESAM IV) in suspected obstructive sleep apnoea. European Respiratory Journal. 1996;9(12):2597-2605. [pmid: 8980975].
29 Koziej M, Cieslicki JK, Gorzelak K, Sliwinski P, Zielinski J. Hand-scoring of MESAM 4 recordings is more accurate than automatic analysis in screening for obstructive sleep apnoea. European Respiratory Journal. 1994;7(10):1771-1775. [pmid: 7828683].
30 Pillar G, Bar A, Betito M, et al. An automatic ambulatory device for detection of AASM defined arousals from sleep: the WP100. Sleep Medicine. 2003;4(3):207-212. [pmid: 14592323].
31 White DP, Gibb TJ, Wall JM, Westbrook PR. Assessment of accuracy and analysis time of a novel device to monitor sleep and breathing in the home.[see comment]. Sleep. 1995;18(2):115-126. [pmid: 7792491].
32 Reichert JA, Bloch DA, Cundiff E, Votteri BA. Comparison of the NovaSom QSG, a new sleep apnea home-diagnostic system, and polysomnography. Sleep Medicine. 2003;4(3):213-218. [pmid: 14592324].
33 Bland JM, Altman DG. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. 1986;1(8476):307-310. [pmid: 2868172].
34 Bland JM, Altman DG. Comparing methods of measurement: why plotting difference against standard method is misleading. Lancet. 1995;346(8982):1085-1087. [pmid: 7564793].
35 Lin LI. A concordance correlation coefficient to evaluate reproducibility. Biometrics. 1989;45(1):255-268. [pmid: 2720055].
36 Lin LI. A note on the concordance correlation coefficient. Biometrics. 2000;56:324-325.
37 Bradley EL, Blackwood LG. Comparing paired data: a simultaneous test for means and variances. Am Statistician. 1989;43:234-235.
38 Jaeschke R, Guyatt GH, Sackett DL. Users' guides to the medical literature. III. How to use an article about a diagnostic test. B. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group. JAMA. 1994;271(9):703-707. [pmid: 8309035].
39 Flemons WW, Littner MR. Measuring agreement between diagnostic devices. Chest. 2003;124(4):1535-1542. [pmid: 14555591].
40 The AASM manual for the scoring of sleep and associated events. Rules, terminology, and technical specifications. Westchester, IL. American Academy of Sleep Medicine. 2007.
41 Sleep-related breathing disorders in adults: recommendations for syndrome definition and measurement techniques in clinical research. The Report of an American Academy of Sleep Medicine Task Force. Sleep. 1999;22(5):667-689. [pmid: 10450601].
42 Wiltshire N, Kendrick AH, Catterall JR. Home oximetry studies for diagnosis of sleep apnea/hypopnea syndrome: limitation of memory storage capabilities. Chest. 2001;120(2):384-389. [pmid: 11502633].
43 Zafar S, Ayappa I, Norman RG, et al. Choice of oximeter affects apnea-hypopnea index. Chest. 2005;127(1):80-88. [pmid: 15653966].
44 Norman RG, Pal I, Stewart C, Walsleben JA, Rapoport DM. Interobserver agreement among sleep scorers from different centers in a large dataset. Sleep. 2000;23(7):901-908. [pmid: 11083599].
45 Collop NA. Scoring variability between polysomnography technologists in different sleep laboratories. Sleep Med. 2002;3(1):43-47. [pmid: 14592253].
46 Pittman SD, MacDonald MM, Fogel RB, et al. Assessment of automated scoring of polysomnographic recordings in a population with suspected sleep-disordered breathing. Sleep. 2004;27(7):1394-1403. [pmid: 15586793].
47 Schaltenbrand N, Lengelle R, Toussaint M, et al. Sleep stage scoring using the neural network model: comparison between visual and automatic analysis in normal subjects and patients. Sleep. 1996;19(1):26-35. [pmid: 8650459].
48 Whitney CW, Gottlieb DJ, Redline S, et al. Reliability of scoring respiratory disturbance indices and sleep staging. Sleep. 1998;21(7):749-757. [pmid: 11286351].
49 Kapur VK, Rapoport DM, Sanders MH, et al. Rates of sensor loss in unattended home polysomnography: the influence of age, gender, obesity, and sleep-disordered breathing. Sleep. 2000;23(5):682-688. [pmid: 10947036].
50 Redline S, Tosteson T, Boucher MA, Millman RP. Measurement of sleep-related breathing disturbances in epidemiologic studies. Assessment of the validity and reproducibility of a portable monitoring device. Chest. 1991;100(5):1281-1286. [pmid: 1935282].
51 Andreas S, von BB, Magnusson K, Kreuzer H. Validation of automated sleep stage and apnoea analysis in suspected obstructive sleep apnoea. European Respiratory Journal. 1993;6(1):48-52. [pmid: 8425594].
52 Calleja JM, Esnaola S, Rubio R, Duran J. Comparison of a cardiorespiratory device versus polysomnography for diagnosis of sleep apnoea. European Respiratory Journal. 2002;20(6):1505-1510. [pmid: 12503711].
53 Carrasco O, Montserrat JM, Lloberes P, et al. Visual and different automatic scoring profiles of respiratory variables in the diagnosis of sleep apnoea-hypopnoea syndrome. European Respiratory Journal. 1996;9(1):125-130. [pmid: 8834345].
54 Dingli K, Coleman EL, Vennelle M, et al. Evaluation of a portable device for diagnosing the sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 2003;21(2):253-259. [pmid: 12608438].
55 Ficker JH, Wiest GH, Wilpert J, Fuchs FS, Hahn EG. Evaluation of a portable recording device (Somnocheck) for use in patients with suspected obstructive sleep apnoea. Respiration. 2001;68(3):307-312. [pmid: 11416253].
56 Fietze I, Glos M, Rottig J, Witt C. Automated analysis of data is inferior to visual analysis of ambulatory sleep apnea monitoring. Respiration. 2002;69(3):235-241. [pmid: 12097767].
57 Zucconi M, Ferini-Strambi L, Castronovo V, Oldani A, Smirne S. An unattended device for sleep-related breathing disorders: validation study in suspected obstructive sleep apnoea syndrome. European Respiratory Journal. 1996;9(6):1251-1256. [pmid: 8804946].
58 Vazquez JC, Tsai WH, Flemons WW, et al. Automated analysis of digital oximetry in the diagnosis of obstructive sleep apnoea. Thorax. 2000;55(4):302-307. [pmid: 10722770].
59 Pittman SD, Ayas NT, MacDonald MM, et al. Using a wrist-worn device based on peripheral arterial tonometry to diagnose obstructive sleep apnea: in-laboratory and ambulatory validation. Sleep. 2004;27(5):923-933. [pmid: 15453551].
60 Meoli AL, Casey KR, Clark RW, et al. Hypopnea in sleep-disordered breathing in adults. Sleep. 2001;24(4):469-470. [pmid: 11403531].
61 Hutter DA, Holland BK, Ashtyani H. Occult sleep apnea: the dilemma of negative polysomnography in symptomatic patients. Sleep Med. 2004;5(5):501-506. [pmid: 15341897].
62 Le Bon O, Hoffmann G, Tecco J, et al. Mild to moderate sleep respiratory events: one negative night may not be enough. Chest. 2000;118(2):353-359. [pmid: 10936124].
63 Quan SF, Griswold ME, Iber C, et al. Short-term variablility of respiration and sleep during unattended nonlaboratory polysomnogaphy--the Sleep Heart Health Study. Sleep. 2002;25(8):843-849. [pmid: 12489889].
64 Lettieri CJ, Eliasson AH, Andrada T, Khramtsov A, Kristo DA. Does zolpidem enhance the yield of polysomnography?. J Clin Sleep Med. 2005;1(2):129-131. [pmid: 17561625].
65 Kingshott RN, Engleman HM, Deary IJ, Douglas NJ. Does arousal frequency predict daytime function?. Eur Respir J. 1998;12(6):1264-1270. [pmid: 9877475].
66 Bennett LS, Langford BA, Stradling JR, Davies RJ. Sleep fragmentation indices as predictors of daytime sleepiness and nCPAP response in obstructive sleep apnea. Am J Respir Crit Care Med. 1998;158(3):778-786. [pmid: 9731004].
67 d'Ortho MP, Grillier-Lanoir V, Levy P, et al. Constant vs. automatic continuous positive airway pressure therapy: home evaluation. Chest. 2000;118(4):1010-1017. [pmid: 11035671].
68 Hermida RC, Zamarron C, Ayala DE, Calvo C. Effect of continuous positive airway pressure on ambulatory blood pressure in patients with obstructive sleep apnoea. Blood Pressure Monitoring. 2004;9(4):193-202. [pmid: 15311146].
69 Lloberes P, Marti S, Sampol G, et al. Predictive factors of quality-of-life improvement and continuous positive airway pressure use in patients with sleep apnea-hypopnea syndrome: study at 1 year. Chest. 2004;126(4):1241-1247. [pmid: 15486388].
70 Marrone O, Salvaggio A, Bonsignore MR, Insalaco G, Bonsignore G. Blood pressure responsiveness to obstructive events during sleep after chronic CPAP. European Respiratory Journal. 2003;21(3):509-514. [pmid: 12662010].
71 Noseda A, Kempenaers C, Kerkhofs M, Houben JJ, Linkowski P. Sleep apnea after 1 year domiciliary nasal-continuous positive airway pressure and attempted weight reduction. Potential for weaning from continuous positive airway pressure. Chest. 1996;109(1):138-143. [pmid: 8549176].
72 Noseda A, Jann E, Hoffmann G, Linkowski P, Kerkhofs M. Compliance with nasal continuous positive airway pressure assessed with a pressure monitor: pattern of use and influence of sleep habits. Respiratory Medicine. 2000;94(1):76-81. [pmid: 10714483].
73 Whitelaw WA, Brant RF, Flemons WW. Clinical usefulness of home oximetry compared with polysomnography for assessment of sleep apnea.[see comment]. American Journal of Respiratory & Critical Care Medicine. 2005;171(2):188-193. [pmid: 15486338].
74 Mulgrew AT, Fox N, Ayas NT, Ryan CF. Diagnosis and initial management of obstructive sleep apnea without polysomnography: a randomized validation study. Annals of Internal Medicine. 2007;146(3):157-166. [pmid: 17283346].
75 Bucher HC, Guyatt GH, Cook DJ, Holbrook A, McAlister FA. Users' guides to the medical literature: XIX. Applying clinical trial results. A. How to use an article measuring the effect of an intervention on surrogate end points. Evidence-Based Medicine Working Group. JAMA. 1999;282(8):771-778. [pmid: 10463714].
76 Ayappa I, Norman RG, Suryadevara M, Rapoport DM. Comparison of limited monitoring using a nasal-cannula flow signal to full polysomnography in sleep-disordered breathing. Sleep. 2004;27(6):1171-1179. [pmid: 15532212].
77 Sokal RR, Rohlf EF. Biometry. New York. Freeman. 1981.
78 Linnet K. Estimation of the linear relationship between the measurements of two methods with proportional errors. Stat Med. 1990;9(12):1463-1473. [pmid: 2281234].
79 Bablok W, Passing H, Bender R, Schneider B. A general regression procedure for method transformation. Application of linear regression procedures for method comparison studies in clinical chemistry, Part III. J Clin Chem Clin Biochem. 1988;26(11):783-790. [pmid: 3235954].
80 Ayas NT, Pittman S, MacDonald M, White DP. Assessment of a wrist-worn device in the detection of obstructive sleep apnea. Sleep Medicine. 2003;4(5):435-442. [pmid: 14592285].
81 Baltzan MA, Verschelden P, Al-Jahdali H, Olha AE, Kimoff RJ. Accuracy of oximetry with thermistor (OxiFlow) for diagnosis of obstructive sleep apnea and hypopnea. Sleep. 2000;23(1):61-69. [pmid: 10678466].
82 Gugger M, Mathis J, Bassetti C. Accuracy of an intelligent CPAP machine with in-built diagnostic abilities in detecting apnoeas: a comparison with polysomnography. Thorax. 1995;50(11):1199-1201. [pmid: 8553278].
83 Zamarron C, Romero PV, Rodriguez JR, Gude F. Oximetry spectral analysis in the diagnosis of obstructive sleep apnoea. Clinical Science. 1999;97(4):467-473. [pmid: 10491347].
84 Zamarron C, Gude F, Barcala J, Rodriguez JR, Romero PV. Utility of oxygen saturation and heart rate spectral analysis obtained from pulse oximetric recordings in the diagnosis of sleep apnea syndrome. Chest. 2003;123(5):1567-1576. [pmid: 12740275].
85 Gagnadoux F, Pelletier-Fleury N, Philippe C, Rakotonanahary D, Fleury B. Home unattended vs hospital telemonitored polysomnography in suspected obstructive sleep apnea syndrome: a randomized crossover trial. Chest. 2002;121(3):753-758. [pmid: 11888956].
86 Iber C, Redline S, Kaplan Gilpin AM, et al. Polysomnography performed in the unattended home versus the attended laboratory setting--Sleep Heart Health Study methodology. Sleep. 2004;27(3):536-540. [pmid: 15164911].
87 Mykytyn IJ, Sajkov D, Neill AM, McEvoy RD. Portable computerized polysomnography in attended and unattended settings. Chest. 1999;115(1):114-122. [pmid: 9925071].
88 Orr WC, Eiken T, Pegram V, Jones R, Rundell OH. A laboratory validation study of a portable system for remote recording of sleep-related respiratory disorders. Chest. 1994;105(1):160-162. [pmid: 8275725].
89 Portier F, Portmann A, Czernichow P, et al. Evaluation of home versus laboratory polysomnography in the diagnosis of sleep apnea syndrome. American Journal of Respiratory & Critical Care Medicine. 2000;162(3:Pt 1):t-8.
90 Ancoli-Israel S, Mason W, Coy TV, et al. Evaluation of sleep disordered breathing with unattended recording: the Nightwatch System. Journal of Medical Engineering & Technology. 1997;21(1):10-14. [pmid: 9080356].
91 Ballester E, Solans M, Vila X, et al. Evaluation of a portable respiratory recording device for detecting apnoeas and hypopnoeas in subjects from a general population. European Respiratory Journal. 2000;16(1):123-127. [pmid: 10933097].
92 Emsellem HA, Corson WA, Rappaport BA, et al. Verification of sleep apnea using a portable sleep apnea screening device. Southern Medical Journal. 1990;83(7):748-752. [pmid: 2371595].
93 Lloberes P, Montserrat JM, Ascaso A, et al. Comparison of partially attended night time respiratory recordings and full polysomnography in patients with suspected sleep apnoea/hypopnoea syndrome. Thorax. 1996;51(10):1043-1047. [pmid: 8977607].
94 Man GC, Kang BV. Validation of a portable sleep apnea monitoring device. Chest. 1995;108(2):388-393. [pmid: 7634872].
95 Marrone O, Salvaggio A, Insalaco G, Bonsignore MR, Bonsignore G. Evaluation of the POLYMESAM system in the diagnosis of obstructive sleep apnea syndrome. Monaldi Archives for Chest Disease. 2001;56(6):486-490. [pmid: 11980277].
96 Parra O, Garcia-Esclasans N, Montserrat JM, et al. Should patients with sleep apnoea/hypopnoea syndrome be diagnosed and managed on the basis of home sleep studies?[see comment]. European Respiratory Journal. 1997;10(8):1720-1724. [pmid: 9272909].
97 Quintana-Gallego E, Villa-Gil M, Carmona-Bernal C, et al. Home respiratory polygraphy for diagnosis of sleep-disordered breathing in heart failure. European Respiratory Journal. 2004;24(3):443-448. [pmid: 15358704].
98 Su S, Baroody FM, Kohrman M, Suskind D. A comparison of polysomnography and a portable home sleep study in the diagnosis of obstructive sleep apnea syndrome. Otolaryngology - Head & Neck Surgery. 2004;131(6):844-850. [pmid: 15577778].
99 Verse T, Pirsig W, Junge-Hulsing B, Kroker B. Validation of the POLY-MESAM seven-channel ambulatory recording unit. Chest. 2000;117(6):1613-1618. [pmid: 10858392].
100 Whittle AT, Finch SP, Mortimore IL, Mackay TW, Douglas NJ. Use of home sleep studies for diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax. 1997;52(12):1068-1073. [pmid: 9516901].
101 Yin M, Miyazaki S, Ishikawa K. Evaluation of type 3 portable monitoring in unattended home setting for suspected sleep apnea: factors that may affect its accuracy. Otolaryngology - Head & Neck Surgery. 2006;134(2):204-209. [pmid: 16455365].
102 Claman D, Murr A, Trotter K. Clinical validation of the Bedbugg in detection of obstructive sleep apnea. Otolaryngol Head Neck Surg. 2001;125(3):227-230. [pmid: 11555758].
103 Adachi H, Mikami A, Kumano-go T, et al. Clinical significance of pulse rate rise during sleep as a screening marker for the assessment of sleep fragmentation in sleep-disordered breathing.[see comment]. Sleep Medicine. 2003;4(6):537-542. [pmid: 14607348].
104 Alvarez D, Hornero R, Abasolo D, del CF, Zamarron C. Nonlinear characteristics of blood oxygen saturation from nocturnal oximetry for obstructive sleep apnoea detection. Physiological Measurement. 2006;27(4):399-412. [pmid: 16537981].
105 Bar A, Pillar G, Dvir I, et al. Evaluation of a portable device based on peripheral arterial tone for unattended home sleep studies.[see comment]. Chest. 2003;123(3):695-703. [pmid: 12628865].
106 Bonsignore G, Marrone O, Macaluso C, et al. Validation of oximetry as a screening test for obstructive sleep apnoea syndrome. European Respiratory Journal - Supplement. 1990;11:542s-544s.
107 Bradley PA, Mortimore IL, Douglas NJ. Comparison of polysomnography with ResCare Autoset in the diagnosis of the sleep apnoea/hypopnoea syndrome. Thorax. 1995;50(11):1201-1203. [pmid: 8553279].
108 Chiner E, Signes-Costa J, Arriero JM, et al. Nocturnal oximetry for the diagnosis of the sleep apnoea hypopnoea syndrome: a method to reduce the number of polysomnographies?[see comment]. Thorax. 1999;54(11):968-971. [pmid: 10525553].
109 Cooper BG, Veale D, Griffiths CJ, Gibson GJ. Value of nocturnal oxygen saturation as a screening test for sleep apnoea. Thorax. 1991;46(8):586-588. [pmid: 1926029].
110 Douglas NJ, Thomas S, Jan MA. Clinical value of polysomnography.[see comment]. Lancet. 1992;339(8789):347-350. [pmid: 1346422].
111 Golpe R, Jimenez A, Carpizo R. Home sleep studies in the assessment of sleep apnea/hypopnea syndrome. Chest. 2002;122(4):1156-1161. [pmid: 12377836].
112 Gurubhagavatula I, Maislin G, Nkwuo JE, Pack AI. Occupational screening for obstructive sleep apnea in commercial drivers. American Journal of Respiratory & Critical Care Medicine. 2004;170(4):371-376. [pmid: 15142866].
113 Gyulay S, Gould D, Sawyer B, et al. Evaluation of a microprocessor-based portable home monitoring system to measure breathing during sleep. Sleep. 1987;10(2):130-142. [pmid: 3589326].
114 Issa FG, Morrison D, Hadjuk E, et al. Digital monitoring of sleep-disordered breathing using snoring sound and arterial oxygen saturation. American Review of Respiratory Disease. 1993;148(4:Pt 1):t-9.
115 Levy P, Pepin JL, schaux-Blanc C, Paramelle B, Brambilla C. Accuracy of oximetry for detection of respiratory disturbances in sleep apnea syndrome. Chest. 1996;109(2):395-399. [pmid: 8620711].
116 Michaelson PG, Allan P, Chaney J, Mair EA. Validations of a portable home sleep study with twelve-lead polysomnography: comparisons and insights into a variable gold standard. Annals of Otology, Rhinology & Laryngology. 2006;115(11):802-809.
117 Overland B, Bruskeland G, Akre H, Skatvedt O. Evaluation of a portable recording device (Reggie) with actimeter and nasopharyngeal/esophagus catheter incorporated. Respiration. 2005;72(6):600-605. [pmid: 15988172].
118 Pang KP, Dillard TA, Blanchard AR, et al. A comparison of polysomnography and the SleepStrip in the diagnosis of OSA. Otolaryngology -Head & Neck Surgery. 2006;135(2):265-268. [pmid: 16890080].
119 Penzel T, Kesper K, Pinnow I, Becker HF, Vogelmeier C. Peripheral arterial tonometry, oximetry and actigraphy for ambulatory recording of sleep apnea. Physiological Measurement. 2004;25(4):1025-1036. [pmid: 15382839].
120 Rauscher H, Popp W, Zwick H. Quantification of sleep disordered breathing by computerized analysis of oximetry, heart rate and snoring. European Respiratory Journal. 1991;4(6):655-659. [pmid: 1889491].
121 Rauscher H, Popp W, Zwick H. Model for investigating snorers with suspected sleep apnoea. Thorax. 1993;48(3):275-279. [pmid: 8497828].
122 Ryan PJ, Hilton MF, Boldy DA, et al. Validation of British Thoracic Society guidelines for the diagnosis of the sleep apnoea/hypopnoea syndrome: can polysomnography be avoided?. Thorax. 1995;50(9):972-975. [pmid: 8539678].
123 Schafer H, Ewig S, Hasper E, Luderitz B. Predictive diagnostic value of clinical assessment and nonlaboratory monitoring system recordings in patients with symptoms suggestive of obstructive sleep apnea syndrome. Respiration. 1997;64(3):194-199. [pmid: 9154670].
124 Series F, Marc I, Cormier Y, La FJ. Utility of nocturnal home oximetry for case finding in patients with suspected sleep apnea hypopnea syndrome.[see comment]. Annals of Internal Medicine. 1993;119(6):449-453. [pmid: 8357109].
125 Stoohs R, Guilleminault C. MESAM 4: an ambulatory device for the detection of patients at risk for obstructive sleep apnea syndrome (OSAS). Chest. 1992;101(5):1221-1227. [pmid: 1582275].
126 Van Surell C, Lemaigre D, Leroy M, et al. Evaluation of an ambulatory device, CID 102, in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal. 1995;8(5):795-800. [pmid: 7656952].
127 Westbrook PR, Levendowski DJ, Cvetinovic M, et al. Description and validation of the apnea risk evaluation system: a novel method to diagnose sleep apnea-hypopnea in the home. Chest. 2005;128(4):2166-2175. [pmid: 16236870].
128 Williams AJ, Yu G, Santiago S, Stein M. Screening for sleep apnea using pulse oximetry and a clinical score. Chest. 1991;100(3):631-635. [pmid: 1889245].
129 Bagnato MC, Nery LE, Moura SM, Bittencourt LR, Tufik S. Comparison of AutoSet and polysomnography for the detection of apnea-hypopnea events. Brazilian Journal of Medical & Biological Research. 2000;33(5):515-519. [pmid: 10775882].
130 Gugger M. Comparison of ResMed AutoSet (version 3.03) with polysomnography in the diagnosis of the sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 1997;10(3):587-591. [pmid: 9072989].
131 Kiely JL, Delahunty C, Matthews S, McNicholas WT. Comparison of a limited computerized diagnostic system (ResCare Autoset) with polysomnography in the diagnosis of obstructive sleep apnoea syndrome. European Respiratory Journal. 1996;9(11):2360-2364. [pmid: 8947086].
132 Mayer P, Meurice JC, Philip-Joet F, et al. Simultaneous laboratory-based comparison of ResMed Autoset with polysomnography in the diagnosis of sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 1998;12(4):770-775. [pmid: 9817143].
133 Rees K, Wraith PK, Berthon-Jones M, Douglas NJ. Detection of apnoeas, hypopnoeas and arousals by the AutoSet in the sleep apnoea/hypopnoea syndrome. European Respiratory Journal. 1998;12(4):764-769. [pmid: 9817142].
134 Shochat T, Hadas N, Kerkhofs M, et al. The SleepStrip: an apnoea screener for the early detection of sleep apnoea syndrome. European Respiratory Journal. 2002;19(1):121-126. [pmid: 11843310].
135 Kushida CA. Clinical presentation, diagnosis, and quality of life issues in restless legs syndrome. Am J Med. 2007;120(1 Suppl 1):S4-S12. [pmid: 17198769].
136 Allen RP, Picchietti D, Hening WA, et al. Restless legs syndrome: diagnostic criteria, special considerations, and epidemiology. A report from the restless legs syndrome diagnosis and epidemiology workshop at the National Institutes of Health. Sleep Med. 2003;4(2):101-119. [pmid: 14592341].
137 Ohayon MM, Roth T. Prevalence of restless legs syndrome and periodic limb movement disorder in the general population. J Psychosom Res. 2002;53(1):547-554. [pmid: 12127170].
138 Mehra R, Strohl KP. Incidence of serious adverse events during nocturnal polysomnography.[see comment]. Sleep. 2004;27(7):1379-1383. [pmid: 15586791].
139 Bearpark H, Elliott L, Grunstein R, et al. Snoring and sleep apnea. A population study in Australian men. American Journal of Respiratory & Critical Care Medicine. 1995;151(5):1459-1465. [pmid: 7735600].
140 Flemons WW, Whitelaw WA, Brant R, Remmers JE. Likelihood ratios for a sleep apnea clinical prediction rule. American Journal of Respiratory & Critical Care Medicine. 1994;150(5:Pt 1):t-85.
141 Fry JM, DiPhillipo MA, Curran K, Goldberg R, Baran AS. Full polysomnography in the home. Sleep. 1998;21(6):635-642. [pmid: 9779523].
142 Hedner J, Pillar G, Pittman SD, et al. A novel adaptive wrist actigraphy algorithm for sleep-wake assessment in sleep apnea patients. Sleep. 2004;27(8):1560-1566. [pmid: 15683148].
143 Ip MS, Lam B, Tang LC, et al. A community study of sleep-disordered breathing in middle-aged Chinese women in Hong Kong: prevalence and gender differences. Chest. 2004;125(1):127-134. [pmid: 14718431].
144 Margel D, Cohen M, Livne PM, Pillar G. Severe, but not mild, obstructive sleep apnea syndrome is associated with erectile dysfunction. Urology. 2004;63(3):545-549. [pmid: 15028455].
145 Masa JF, Rubio M, Findley LJ. Habitually sleepy drivers have a high frequency of automobile crashes associated with respiratory disorders during sleep. American Journal of Respiratory & Critical Care Medicine. 2000;162(4:Pt 1):t-12.
146 Middelkoop HA, Knuistingh NA, van Hilten JJ, Ruwhof CW, Kamphuisen HA. Wrist actigraphic assessment of sleep in 116 community based subjects suspected of obstructive sleep apnoea syndrome. Thorax. 1995;50(3):284-289. [pmid: 7660344].
147 Neven AK, Middelkoop HA, Kemp B, Kamphuisen HA, Springer MP. The prevalence of clinically significant sleep apnoea syndrome in The Netherlands. Thorax. 1998;53(8):638-642. [pmid: 9828848].
148 Series F, Marc I. Nasal pressure recording in the diagnosis of sleep apnoea hypopnoea syndrome.[see comment]. Thorax. 1999;54(6):506-510. [pmid: 10335004].