# References

1 CDC. National Diabetes Fact Sheet. 2005.
2 Cowie CC, Rust KF, Byrd-Holt DD, et al. Prevalence of diabetes and impaired fasting glucose in adults in the U.S. population: National Health And Nutrition Examination Survey 1999–2002. Diabetes Care. June. 2006;29(6):61263-8.
3 Narayan KM, Boyle JP, Thompson TJ, et al. Lifetime risk for diabetes mellitus in the United States. JAMA. 2003;290(14):1884-90. [pmid: 14532317].
4 Manuel DG, Schultz SE. Health-related quality of life and health-adjusted life expectancy of people with diabetes in Ontario, Canada, 1996–1997. Diabetes Care. 2004;27(2):407-14. [pmid: 14747221].
5 US Renal Data System. USRDS 2002 annual data report. National Institutes of Health, National Institute of Diabetes and Digestive Diseases. Bethesda MD. 2002.
6 Hillier TA, Pedula KL. Complications in young adults with early-onset type 2 diabetes. Diabetes Care. 2003;26:2999-3005. [pmid: 14578230].
7 Hogan P, Dall T, Nikolov P, et al. Economic costs of diabetes in the US in 2002. Diabetes Care. 2003;26(3):917-32. [pmid: 12610059].
8 Zammitt NN, Frier BM. Hypoglycemia in type 2 diabetes: pathophysiology, frequency, and effects of different treatment modalities. [Review] [151 refs]. Diabetes Care. 2005;28(12):2948-61. [pmid: 16306561].
9 Cryer PE, Davis SN, Shamoon H. Hypoglycemia in diabetes. Diabetes Care. 2003;26(6):1902-12. [pmid: 12766131].
10 Pramming S, Thorsteinsson B, Bendtson I, et al. Symptomatic hypoglycaemia in 411 type 1 diabetic patients. Diabetic Medicine. 1991;8(3):217-22. [pmid: 1828735].
11 The Diabetes Control and Complications Trial Research Group. The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. New England Journal of Medicine. 1993;329(14):977-86. [pmid: 8366922].
12 UK Prospective Diabetes Study (UKPDS) Group. Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). Lancet. 1998;352(9131):837-53. [pmid: 9742976].
13 Haffner SM, Lehto S, Ronnemaa T, et al. Mortality from coronary heart disease in subjects with type 2 diabetes and in nondiabetic subjects with and without prior myocardial infarction. N Engl J Med. 1998;339(4):229-34. [pmid: 9673301].
14 UK Prospective Diabetes Study (UKPDS) Group. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). Lancet. 1998;352(9131):854-65. [pmid: 9742977].
15 Dormandy JA, Charbonnel B, Eckland DJ, et al. Secondary prevention of macrovascular events in patients with type 2 diabetes in the PROactive Study (PROspective pioglitAzone Clinical Trial In macroVascular Events): a randomised controlled trial. Lancet. 2005;366(9493):1279-89. [pmid: 16214598].
16 Gerstein HC, Yusuf S, Bosch J, et al. Effect of rosiglitazone on the frequency of diabetes in patients with impaired glucose tolerance or impaired fasting glucose: a randomised controlled trial. Lancet. 2006;368(9541):1096-105. [pmid: 16997664].
17 Kahn SE, Haffner SM, Heise MA, et al. Glycemic durability of rosiglitazone, metformin, or glyburide monotherapy. N Engl J Med. 2006;355(23):2427-43. [pmid: 17145742].
18 Home PD, Pocock SJ, Beck-Nielsen H, et al. Rosiglitazone evaluated for cardiovascular outcomes--an interim analysis. N Engl J Med. 2007;357(1):28-38. [pmid: 17551159].
19 Sever PS, Poulter NR, Dahlof B, et al. Reduction in cardiovascular events with atorvastatin in 2,532 patients with type 2 diabetes: Anglo-Scandinavian Cardiac Outcomes Trial--lipid-lowering arm (ASCOT-LLA). Diabetes Care. 2005;28(5):1151-7. [pmid: 15855581].
20 Fox CS, Coady S, Sorlie PD, et al. Trends in cardiovascular complications of diabetes. JAMA. 2004;292(20):2495-9. [pmid: 15562129].
21 Haffner SM, Lehto S, Ronnemaa T, et al. Mortality from coronary heart disease in subjects with type 2 diabetes and in nondiabetic subjects with and without prior myocardial infarction. N Engl J Med. 1998;339(4):229-34. [pmid: 9673301].
22 Saudek CD, Derr RL, Kalyani RR. Assessing Glycemia in Diabetes Using Self-monitoring Blood Glucose and Hemoglobin A_1c_. JAMA. 2006;295(14):1688-97. [pmid: 16609091].
23 Lewandrowski K, Cheek R, Nathan DM, et al. Implementation of capillary blood glucose monitoring in a teaching hospital and determination of program requirements to maintain quality testing. American Journal of Medicine. 1992;93(4):419-26. [pmid: 1415305].
24 Arabadjief D, Nichols JH. Assessing glucose meter accuracy. [Review] [20 refs]. Current Medical Research & Opinion. 2006;22(11):2167-74. [pmid: 17076977].
25 Deiss D, Hartmann R, Schmidt J, et al. Results of a Randomised Controlled Cross-Over Trial on the Effect of Continuous Subcutaneous Glucose Monitoring (CGMS) on Glycaemic Control in Children and Adolescents with Type 1 Diabetes. Experimental & Clinical Endocrinology & Diabetes. 2006;114(2):63-7. [pmid: 16570235].
26 Lagarde WH, Barrows FP, Davenport ML, et al. Continuous subcutaneous glucose monitoring in children with type 1 diabetes mellitus: a single-blind, randomized, controlled trial. Pediatric Diabetes. 2006;7(3):159-64. [pmid: 16787523].
27 Yates K, Hasnat MA, Dear K, et al. Continuous glucose monitoring-guided insulin adjustment in children and adolescents on near-physiological insulin regimens: a randomized controlled trial. Diabetes Care. 2006;29(7):1512-7. [pmid: 16801571].
28 FDA News. FDA approves Glucowatch device for children with diabetes. http://www.fda.gov/bbs/topics/NEWS/2002/NEW00830.html. accessed Aug. 10, 2006. 2006.
29 Potts RO, Tamada JA, Tierney MJ. Glucose monitoring by reverse iontophoresis. Diabetes/Metabolism Research Reviews. 2002;18(Suppl 1):S49-S53. [pmid: 11921430].
30 Evans JM, Newton RW, Ruta DA, et al. Frequency of blood glucose monitoring in relation to glycaemic control: observational study with diabetes database. BMJ. 1999;319(7202):83-6. [pmid: 10398627].
31 Haller MJ, Stalvey MS, Silverstein JH. Predictors of control of diabetes: monitoring may be the key. Journal of Pediatrics. 2004;144(5):660-1. [pmid: 15127007].
32 Karter AJ, Ackerson LM, Darbinian JA, et al. Self-monitoring of blood glucose levels and glycemic control: the Northern California Kaiser Permanente Diabetes registry. American Journal of Medicine. 2001;111(1):1-9. [pmid: 11448654].
33 Soumerai SB, Mah C, Zhang F, et al. Effects of health maintenance organization coverage of self-monitoring devices on diabetes self-care and glycemic control. Archives of Internal Medicine. 2004;164(6):645-52. [pmid: 15037493].
34 Levine BS, Anderson BJ, Butler DA, et al. Predictors of glycemic control and short-term adverse outcomes in youth with type 1 diabetes. [see comment]. Journal of Pediatrics. 2001;139(2):197-203. [pmid: 11487743].
35 Schiffrin A, Belmonte M. Multiple daily self-glucose monitoring: its essential role in long-term glucose control in insulin-dependent diabetic patients treated with pump and multiple subcutaneous injections. Diabetes Care. 1982;5(5):479-84. Oct. [pmid: 6765224].
36 American Association of Clinical Endocrinologists. The American Association of Clinical Endocrinologists Medical Guidelines for the Management of Diabetes Mellitus: the AACE system of intensive diabetes self-management--2000 update. Endocrine Practice. 2000;6(1):43-84. [pmid: 11428359].
37 American Diabetes Association. Standards of Medical Care in Diabetes 2006. 2006.
38 American Academy of Family Physicians.
39 Canadian Diabetes Association. Clinical Practice Guidelines 2003. 2006.
40 Nyomba BL, Berard L, Murphy LJ. Facilitating access to glucometer reagents increases blood glucose self-monitoring frequency and improves glycaemic control: a prospective study in insulin-treated diabetic patients. Diabetic Medicine. 2004;21(2):129-35. [pmid: 14984447].
41 Writing Team for the Diabetes Control and Complications Trial - Epidemiology of Diabetes Interventions and Complications Research Group. Effect of intensive therapy on the microvascular complications of type 1 diabetes mellitus. JAMA. 2002;287(19):2563-9. [pmid: 12020338].
42 The relationship of glycemic exposure (HbA1c) to the risk of development and progression of retinopathy in the diabetes control and complications trial. Diabetes. 1995;44(8):968-83. [pmid: 7622004].
43 The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial. Diabetes. 1996;45(10):1289-98. [pmid: 8826962].
44 Nathan DM, Cleary PA, Backlund JY, et al. Intensive diabetes treatment and cardiovascular disease in patients with type 1 diabetes. [see comment]. New England Journal of Medicine. 2005;353(25):2643-53. [pmid: 16371630].
45 Pitale S, Kernan-Schroeder D, Emanuele N, et al. Health-related quality of life in the VA Feasibility Study on glycemic control and complications in type 2 diabetes mellitus. Journal of Diabetes & its Complications. 2005;19(4):207-11. [pmid: 15993354].
46 Azad N, Emanuele NV, Abraira C, et al. The effects of intensive glycemic control on neuropathy in the VA cooperative study on type II diabetes mellitus (VA CSDM). Journal of Diabetes & its Complications. 1999;13(5–6):307-13. [pmid: 10765007].
47 Abraira C, Henderson WG, Colwell JA, et al. Response to intensive therapy steps and to glipizide dose in combination with insulin in type 2 diabetes. VA feasibility study on glycemic control and complications (VA CSDM). Diabetes Care. 1998;21(4):574-9. [pmid: 9571345].
48 Abraira C, Colwell JA, Nuttall FQ, et al. Veterans Affairs Cooperative Study on glycemic control and complications in type II diabetes (VA CSDM). Results of the feasibility trial. Veterans Affairs Cooperative Study in Type II Diabetes. Diabetes Care. 1995;18(8):1113-23. [pmid: 7587846].
49 Abraira C, Colwell J, Nuttall F, et al. Cardiovascular events and correlates in the Veterans Affairs Diabetes Feasibility Trial. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type II Diabetes. Archives of Internal Medicine. 1997;157(2):181-8. [pmid: 9009975].
50 Emanuele N, Klein R, Abraira C, et al. Evaluations of retinopathy in the VA Cooperative Study on Glycemic Control and Complications in Type II Diabetes (VA CSDM). A feasibility study. [see comment]. Diabetes Care. 1996;19(12):1375-81. [pmid: 8941467].
51 Colwell JA. The feasibility of intensive insulin management in non-insulin-dependent diabetes mellitus. Implications of the Veterans Affairs Cooperative Study on Glycemic Control and Complications in NIDDM. Annals of Internal Medicine. 1996;124(1:Pt 2):t-5.
52 Shichiri M, Kishikawa H, Ohkubo Y, et al. Long-term results of the Kumamoto Study on optimal diabetes control in type 2 diabetic patients. Diabetes Care. 2000;23:Suppl-9.
53 Quality of life in type 2 diabetic patients is affected by complications but not by intensive policies to improve blood glucose or blood pressure control (UKPDS 37). U.K. Prospective Diabetes Study Group. Diabetes Care. 1999;22(7):1125-36. [pmid: 10388978].
54 Wright A, Burden AC, Paisey RB, et al. Sulfonylurea inadequacy: efficacy of addition of insulin over 6 years in patients with type 2 diabetes in the U.K. Prospective Diabetes Study (UKPDS 57). [see comment][erratum appears in Diabetes Care 2002 Jul;25(7):1268]. Diabetes Care. 2002;25(2):330-6. [pmid: 11815505].
55 van der Does FE, de Neeling JN, Snoek FJ, et al. Randomized study of two different target levels of glycemic control within the acceptable range in type 2 diabetes. Effects on well-being at 1 year. Diabetes Care. 1998;21(12):2085-93. [pmid: 9839098].
56 de Sonnaville JJ, Bouma M, Colly LP, et al. Sustained good glycaemic control in NIDDM patients by implementation of structured care in general practice: 2-year follow-up study. Diabetologia. 1997;40(11):1334-40. [pmid: 9389427].
57 Goddijn PP, Bilo HJ, Feskens EJ, et al. Longitudinal study on glycaemic control and quality of life in patients with Type 2 diabetes mellitus referred for intensified control. Diabetic Medicine. 1999;16(1):23-30. [pmid: 10229289].
58 Saudek CD, Duckworth WC, Giobbie-Hurder A, et al. Implantable insulin pump vs multiple-dose insulin for non-insulin-dependent diabetes mellitus: a randomized clinical trial. Department of Veterans Affairs Implantable Insulin Pump Study Group. [see comment]. JAMA. 1996;276(16):1322-7. [pmid: 8861991].
59 Albisser AM, Harris RI, Albisser JB, et al. The impact of initiatives in education, self-management training, and computer-assisted self-care on outcomes in diabetes disease management. Diabetes Technology & Therapeutics. 2001;3(4):571-9. [pmid: 11911169].
60 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. [see comment]. New England Journal of Medicine. 1993;329(14):977-86. [pmid: 8366922].
61 Guerci B, Drouin P, Grange V, et al. Self-monitoring of blood glucose significantly improves metabolic control in patients with type 2 diabetes mellitus: the Auto-Surveillance Intervention Active (ASIA) study. Diabetes & Metabolism. 2003;29(6):587-94. [pmid: 14707887].
62 Fontbonne A, Billault B, Acosta M, et al. Is glucose self-monitoring beneficial in non-insulin-treated diabetic patients? Results of a randomized comparative trial. Diabete et Metabolisme. 1989;15(5):255-60. [pmid: 2630378].
63 Davidson MB, Castellanos M, Kain D, et al. The effect of self monitoring of blood glucose concentrations on glycated hemoglobin levels in diabetic patients not taking insulin: a blinded, randomized trial. American Journal of Medicine. 2005;118(4):422-5. [pmid: 15808142].
64 Schwedes U, Siebolds M, Mertes G, et al. Meal-related structured self-monitoring of blood glucose: effect on diabetes control in non-insulin-treated type 2 diabetic patients. Diabetes Care. 2002;25(11):1928-32. [pmid: 12401734].
65 Kibriya MG, Ali L, Banik NG, et al. Home monitoring of blood glucose (HMBG) in Type-2 diabetes mellitus in a developing country. Diabetes Research & Clinical Practice. 1999;46(3):253-7. [pmid: 10624792].
66 Rutten G, van Eijk J, de Nobel E, et al. Feasibility and effects of a diabetes type II protocol with blood glucose self-monitoring in general practice. Family Practice. 1990;7(4):273-8. [pmid: 2289639].
67 Banister NA, Jastrow ST, Hodges V, et al. Diabetes self-management training program in a community clinic improves patient outcomes at modest cost. Journal of the American Dietetic Association. 2004;104(5):807-10. [pmid: 15127069].
68 Franciosi M, Pellegrini F, De Berardis G, et al. Self-monitoring of blood glucose in non-insulin-treated diabetic patients: a longitudinal evaluation of its impact on metabolic control. Diabetic Medicine. 2005;22(7):900-6. [pmid: 15975106].
69 Halimi S, Charpentier G, Grimaldi A, et al. Effect on compliance, acceptability of blood glucose self-monitoring and HbA(1c) of a self-monitoring system developed according to patient’s wishes. The ACCORD study. Diabetes & Metabolism. 2001;27(6):681-7. [pmid: 11852377].
70 Miles P, Everett J, Murphy J, et al. Comparison of blood or urine testing by patients with newly diagnosed non-insulin dependent diabetes: patient survey after randomised crossover trial. [erratum appears in BMJ 1998 Jan 17;316(7126):195]. BMJ. 1997;315(7104):348-9. [pmid: 9270457].
71 Ozmen B, Boyvada S. The relationship between self-monitoring of blood glucose control and glycosylated haemoglobin in patients with type 2 diabetes with and without diabetic retinopathy. Journal of Diabetes & its Complications. 2003;17(3):128-34. [pmid: 12738396].
72 Murata GH, Duckworth WC, Shah JH, et al. Factors affecting hypoglycemia awareness in insulin-treated type 2 diabetes: The Diabetes Outcomes in Veterans Study (DOVES). Diabetes Research & Clinical Practice. 2004;65(1):61-7. [pmid: 15163479].
73 Cox DJ, Kovatchev BP, Julian DM, et al. Frequency of severe hypoglycemia in insulin-dependent diabetes mellitus can be predicted from self-monitoring blood glucose data. Journal of Clinical Endocrinology & Metabolism. 1994;79(6):1659-62. [pmid: 7989471].