# Summary and Discussion

## Summary of findings

### Question A

Through the systematic review process, describe the applicability of the literature to the non-dialysis-dependent Medicare population in regards to

The relationship between tighter glycemic control and clinical outcomes (both benefits and harms) in patients with type 2 diabetes.

#### Clinical events

##### Study descriptions and applicability to Medicare population

For the purposes of this report, we included all prospective studies of intensive glycemic control in predominantly patients with type 2 diabetes with a minimum sample size of 100 patients followed for at least 1 year.

Three randomized controlled trials met eligibility criteria, including the large UKPDS trial. Although all trials included at least some patients age 65 or older, these patients represented a small minority overall. Furthermore, no study performed separate analyses for older patients. Notably, the UKPDS trial included only patients with newly diagnosed diabetes, with a mean baseline HbA1c of 7%. The baseline HbA1c in the other two trials was approximately 9%; however one study was performed among relative thin Japanese patients, a population that may be of only limited applicability to the large majority of American patients with type 2 diabetes. The use of insulin, other antidiabetic treatments, and the prevalence of diabetes-related comorbidities varied widely (or were not reported) among the studies. Each trial used a different goal for intensive glycemic control using a variety of measures of glycemia.

##### Summary of results

Only the UKPDS trial had sufficient participants to begin to make a precise estimate of mortality. The trial found nonsignificant trends for decreased all-cause and diabetes-related mortality rates with intensive glycemic control at about 10 years follow-up. The other two trials found no difference in mortality. Similarly UKPDS found marginally significant reductions in nonfatal and total myocardial infarctions, and fatal sudden death events. No differences were found for other cardiovascular events and the other two trials found no differences for all cardiovascular events.

Only the Japanese study Shichiri 2000 was designed primarily to investigate retinopathy. They reported that intensive glycemic control resulted in substantial reductions in progression of retinopathy after 8 years; however, no significant differences were found in development of preproliferative or proliferative retinopathy. UKPDS found a significant reduction in the need for retinal photocoagulation after about 10 years with intensive glycemic control, but no difference in vitreous hemorrhage or blindness events. VA CSDM found that patients on intensive glycemic control had increased retinopathy progression over the first year, but reduced progression in the second year.

UKPDS found no difference in rates of kidney failure over 10 years, but the other trials reported slower progression of microalbuminuria after 2 years and less progression of nephropathy at 8 years with intensive treatment. No statistically significant differences were reported in a wide range of neuropathy events in two trials.

The studies do not provide evidence for any improvements in retinopathy or kidney function with intensive glycemic control.

##### Correlation of level of glycemic control and clinical outcomes

From the three trials, there is evidence to suggest long-term reductions in microvascular events (i.e., retinopathy and kidney disease) and macrovascular events (i.e., cardiac and stroke events) with progressively improved glycemic control; however, data from the VA CDSM trial suggest that that a transient increase in cardiovascular events may occur with the introduction of intensive glycemic control.

#### Severe hypoglycemia

##### Study descriptions and applicability to Medicare population

For the purposes of this report, we included all prospective studies of intensive glycemic control in predominantly patients with type 2 diabetes with a minimum sample size of 50 patients followed for at least 3 months.

Nine studies met criteria, of which five were randomized controlled trials, one a nonrandomized controlled study, and three uncontrolled cohort studies. Two of the trials (both from UKPDS) included only subjects with newly diagnosed type 2 diabetes. The mean HbA1c reported ranged from about 7% to 10%. There was a wide range across studies of insulin use and other antidiabetic treatments; one study did not report how many subjects had type 2 diabetes and likely included at least some with type 1 diabetes. The prevalence of diabetes-related comorbidities varied widely (or were not reported) among the studies. All studies included at least some patients 65 years or older, but the largest trials (UKPDS) set 65 years old as a maximum age at enrollment. No study performed separate analyses for older patients. Each study used a different goal for intensive glycemic control using a variety of measures of glycemia.

##### Summary of results

All studies reported on “severe” hypoglycemic episodes, sometimes defined as grade 3 or 4, sometimes as “requiring assistance,” but sometimes not further defined. The two UKPDS trials and the nonrandomized controlled study, all relatively large, provide evidence that severe hypoglycemic episodes are statistically significantly (or at least substantially) more common among patients being treated with intensive glycemic control. On the order of 1–2 percent of patients using intensive glycemic control had episodes of severe hypoglycemia. Among the studies that reported any severe hypoglycemic events and reported results per 100 patient-years, the rates with multidose insulin were less than 1 event per 100 patient-years. This can be contrasted with the 62 severe hypoglycemic episodes per 100 patient-years found in DCCT among patients with type 1 diabetes.60 It is unclear whether the lack of difference in effect of the other comparative trials was due to differences in the studies or to an insufficient number of subjects to detect possible differences. However, it is notable, that the three studies (possibly) conducted most recently both report no episodes of severe hypoglycemic episodes among a large number of subjects.

##### Correlation of level of glycemic control and hypoglycemia

Four studies analyzed correlations between either achieved HbA1c or change in HbA1c and hypoglycemia outcomes. Importantly, though, none analyzed the outcome of interest, grade 3 or higher episodes of hypoglycemia. While one study suggests an exponential increase in hypoglycemia episodes with continually decreasing HbA1c below approximately 8%, overall the evidence weakly suggests only a possible correlation between tightness of glycemic control and frequency of hypoglycemia episodes.

### Question B

Through the systematic review process, describe the applicability of the literature to the non-dialysis-dependent Medicare population in regards to

The effect of frequency of glucose monitoring on clinical outcomes in patients with type 2 diabetes.

#### Clinical events

For the purposes of this report, we searched for all prospective studies of self-monitoring of blood glucose (SMBG) in predominantly patients with type 2 diabetes with a minimum sample size of 100 patients followed for at least 1 year. No study met eligibility criteria.

#### Severe hypoglycemia

##### Study descriptions and applicability to Medicare population

For the purposes of this report, we included all prospective studies of intensive glycemic control in predominantly patients with type 2 diabetes with a minimum sample size of 50 patients followed for at least 3 months.

Three uncontrolled cohort studies met criteria. The frequency of monitoring ranged from about 14 to 28 times per week. All patients used insulin, but only one study explicitly included only patients with type 2 diabetes. This latter study had a mean age of 65 years, though no subanalyses were performed in this group. It is likely that the other two studies included a sizeable number of patients with type 1 diabetes, particularly since the mean age at enrollment was about 40 in both studies. The mean duration of diabetes in all studies was about 14 to 19 years. The mean baseline HbA1c levels ranged from about 8% to 10%. None of the studies was clear about how patients and clinicians changed diabetes management based on the SMBG readings.

##### Summary of results

In the one study clearly of only people with type 2 diabetes, about half of the patients suffered from symptomatic hypoglycemia (including episodes not requiring assistance from others) during 1 year of using SMBG. Among the other two studies, about three-quarters of the patients reported grade 3 or 4 hypoglycemia episodes in one 6-month study and the number of weekly hypoglycemic episodes increased by an average of four episodes during 6 months in the study.

##### Correlation of SMBG frequency and hypoglycemia

No study attempted to correlate SMBG frequency with hypoglycemia episodes.

### Question C

Through the systematic review process, describe the applicability of the literature to the non-dialysis-dependent Medicare population in regards to

The effect of frequency of glucose monitoring on glycemic control (HbA1c) in patients with type 2 diabetes.

#### Study descriptions and applicability to Medicare population

For the purposes of this report, we included all prospective studies of intensive glycemic control in predominantly patients with type 2 diabetes with a minimum sample size of 50 patients followed for at least 3 months.

Five randomized controlled trials, one nonrandomized controlled study, and five single-arm, uncontrolled cohort studies met eligibility criteria. The frequency of glucose monitoring in the experimental arms or the cohort studies was highly variable, ranging from 2–3 daily measurements every two weeks to about six measurements per day. Only one of the trials and two of the other studies report that adjustments to antidiabetic treatments were made based on SMBG readings. The nonrandomized comparative study was an observational study, with no specific protocol regarding SMBG.

In the randomized trials, fewer than half the participants were aged 65 years or older at enrollment; most of the other studies also included a majority of patients under age 65. One of the cohort studies may have included patients with type 1 diabetes. Among the randomized trials, the mean duration of diabetes ranged from about 5 to 10 years; among the other studies some included only patients with newly diagnosed diabetes. The data on comorbidities were generally not reported. Across studies, the mean baseline HbA1c levels ranged from 7% to 10%.

#### Summary of results

The randomized trials provide inconclusive evidence that use of SMBG may result in a small, possibly clinically nonsignificant, decrease in HbA1c, on the order of a 0.25% to 0.5% decrease. Although some of the nonrandomized studies found larger decreases in HbA1c with SMBG use, these studies were generally in agreement with the randomized trials regarding the change in HbA1c. There was no clear pattern across studies regarding how the intensity of the SMBG protocols (frequency of monitoring) or baseline HbA1c related to net changes in HbA1c. The studies were each very different in how frequently (and on which days) SMBG was performed. In addition, given that most of the studies did not report how patients or clinicians changed their behavior or treatments, these analyses do not explain how the use of SMBG resulted in improved HbA1c.

As a point of reference, the prospective trials generally found smaller net effects of SMBG than the two large retrospective database analyses from Kaiser Permanente32 and Harvard Pilgrim33 health maintenance organizations. The Kaiser Permanente study reported that people with type 2 diabetes who filled prescriptions equivalent to at least 0.75 strips per day had HbA1c levels between 0.4% and 0.6% lower than those with “inadequate” use, depending on their diabetes treatment regimen (approximately 23,000 subjects).32 The Harvard Pilgrim study evaluated a mix of people with types 1 and 2 diabetes (725 subjects) and reported that initiation of SMBG was not associated with improved HbA1c levels in those with good (HbA1c ≤ 8.0%) or adequate (8–10%) baseline glycemic control, but among those with poor baseline glycemic control (>10%), initiators of SMBG lowered their mean HbA1c level by 0.63% compared with noninitiators (P = .03).33

Of note, no eligible study evaluated continuous glucose monitoring or other home blood glucose measurement techniques.

#### Correlation of SMBG frequency and HbA1c

Two of the studies on SMBG reported analyses correlating SMBG frequency with achieved HbA1c. However, as one study that did not have a protocol regarding SMBG use found only a trend, and the other study relied on number of test strips used as a proxy for frequency and performed an analysis that may have been driven by an extreme point, no firm conclusions can be drawn about the correlation between frequency of SMBG testing and achieved HbA1c.

## Discussion

The eligibility criteria for this report were strict, requiring relatively large numbers of subjects and long-term follow-up. Thus, this report reviews only the studies that are likely to provide the “strongest” evidence. Many studies were not reviewed because of small sample size or shorter-term follow-up. The report included only five randomized trials of intensive glycemic control, only three of which provided data on clinical events, and five randomized trials of SMBG, none of which provided data on either clinical events or hypoglycemic episodes. In fact, no study met eligibility criteria that evaluated SMBG and clinical events. A small number of studies evaluated correlations between either intensity of glycemic controlled (measured by HbA1c) or frequency of self-monitoring and outcomes of interest for this report. No eligible study evaluated continuous glucose monitoring.

The applicability of these studies to the nondialysis-dependent Medicare population is debatable. Using only age as a criterion, most studies included only a minority of participants of age 65 years or older at enrollment. Studies commonly had only a small percentage of older patients, where mean age was less than about 55 years. The largest study, UKPDS (trial 1) enrolled patients with a maximum age of 65 years. No study performed subanalyses of the Medicare-eligible population. The applicability of this trial to the Medicare population is further limited by the fact that only patients with newly diagnosed diabetes (thus with “moderate” HbA1c of about 7%) were enrolled. Other than the UKPDS trials, the duration of diabetes in most studies was on the order of 10 years and most studies had mean HbA1c levels at enrollment of about 8% to 10%. However, it is difficult to compare most of the studies to Medicare population based on other factors. Prevalence of comorbidities, such as cardiovascular, kidney, eye, and peripheral nerve disease, were generally not reported. In addition, insulin use at baseline ranged widely from 0 to 100 percent of subjects, based on varying eligibility criteria and treatment practices. As highlighted by the Japanese study of relatively thin patients with type 2 diabetes, it is likely that the studies varied in the degree to which patients were insulin deficient compared with their insulin sensitivity. It was difficult to pinpoint when most studies were performed since this was generally not reported. However, the UKPDS trial was run from 1977 to 1991 and only three cohort studies were definitely conducted in the last decade (although four other cohort studies and four randomized trials were probably conducted in the last decade).

Regarding the effect of these two interventions among patients with type 2 diabetes, the reviewed studies generally found that intensive glycemic control may result in reduced mortality and certain cardiac events, progression of retinopathy (after about 1 year), and progression of nephropathy. No effect was found for various cardiovascular events, blindness events, kidney failure, or neuropathy. No evidence was reported regarding possible improvement in retinopathy or kidney function with treatment. Among older studies, there is evidence that intensive glycemic control is strongly associated with episodes of severe hypoglycemia; however, since no episodes were reported among more recent studies, it is possible that with newer treatment protocols or training methods, the risk of severe hypoglycemic episodes is now very low. The reported rates of severe hypoglycemia were orders of magnitude smaller than the rates found in DCCT among patients with type 1 diabetes. There is no clear evidence regarding the rate of severe hypoglycemia with SMBG use among patients with type 2 diabetes. Evidence from randomized and uncontrolled studies were inconclusive about whether SMBG use results in clinically significant reductions of HbA1c; the two largest randomized trials found statistically significant net reductions of less than 0.5%. Furthermore, the studies of SMBG are generally difficult to interpret since the links between SMBG use and changes in antidiabetes management, resulting in changes in glycemia, are not described and the SMBG protocols varied widely across studies. The studies generally poorly reported the degree of patient education or what the patients were told to do with the information from SMBG, complicating interpretation of their results. No clear association across studies was found between the intensity of the SMBG protocols and net reduction of HbA1c.

Over the long term, three studies did find that the level of glycemic control achieved correlated with improved micro- and macrovascular outcomes, although there may be a transient increase in cardiovascular events with the introduction of glycemic control. The studies that analyzed intensity of glycemic control and risk of hypoglycemia did not specifically evaluate severe hypoglycemic episodes. No firm conclusions could be reached from the two studies that analyzed correlations between frequency of SMBG use and achieved HbA1c levels.

Overall, the assessed studies generally found that among patients with type 2 diabetes, that intensive glycemic control results in reduces risks for various clinical events, but there are no data on the effects of SMBG on clinical outcomes. SMBG use may result in only clinically nonsignificant improvements in achieved glycemic control. Intensive glycemic control may result in increased episodes of severe hypoglycemia, but there are insufficient data on SMBG use in patients with type 2 diabetes and severe hypoglycemia. Also, more intensive glycemic control is more strongly associated with outcomes than lesser interventions, but the data regarding SMBG frequency and achieved HbA1c are inconclusive. Overall, the degree to which these studies are applicable to patients 65 years of age and older, who may have more severe comorbidities, a shorter life expectancy, and more cognitive, visual, and social difficulties than study patients is unclear.