# Results

## Results of Literature Search

(Figure 1)

Figure 1 Flowchart of articles screened and evaluated

Figure 1. Flowchart of articles screened and evaluated

Through our MEDLINE searches, we identified and screened 7,551 abstracts; an additional 11 articles were found from other sources. Of these, 293 apparently pertained to patients with diabetes being managed with tightened glycemic control and/or self-monitoring of blood glucose (SMBG). Of these, 154 articles of primary studies and 36 review articles were retrieved, from which, 30 articles representing 22 studies met eligibility criteria. Reasons for exclusion of the remaining retrieved articles (See Appendix A) included: sample size too small or study duration too short (35 articles), wrong population (32 articles), retrospective or cross-sectional design (21 articles), no intervention or outcome of interest (22 articles), being a letter or having no primary data (8 articles), or being a duplicate publication with no additional data of interest for this report (6 articles). Of the remaining (unretrieved) 103 abstracts, 38 were rejected for being either retrospective, cross-sectional, or of the wrong population (e.g., type 1 diabetes, children, or dialysis-dependent); 65 were rejected for including fewer than 50 participants. Of note, the screening process occurred in parallel with the key question formulation process, such that many articles were retrieved that did not meet final eligibility criteria.

Among the 22 eligible articles, nine evaluated intensive glycemic control. Three of these studies met criteria and included clinical outcomes of interest; eight met criteria for hypoglycemia outcomes; and three evaluated correlations between achieved glycemic control and outcomes of interest. Thirteen studies evaluated SMBG. None of these studies included clinical outcomes of interest; three met criteria for hypoglycemia outcomes; 11 met criteria for glycemia outcomes; and two evaluated correlations between frequency of self-monitoring and outcomes of interest. Of note, no study that met eligibility criteria evaluated continuous glucose monitoring.

## Intensive glycemic control and clinical events in patients with type 2 diabetes

(Table 3)

Table 3 Studies of intensive glycemic control and clinical outcomes

3.a Applicability of “large” prospective studies to non-dialysis-dependent Medicare population (baseline data)

Author, Year UI | N | Mean Age (Range) | ~%≥65 yr | Mean Duration DM | % DM 2 | % Using Insulin
UKPDS trial 1 9742976^12^ 9742977^14^ | 3867 | 53 (25–65)^a^ | ~0% | “Newly diagnosed” | 100% | 0%
VA CSDM trial (7 publications) 45–51 | 153 | 60 (40–69)^a^ | <50% | 7.9 yr (all<15 yr) | 100% | 59%
Shichiri, 2000 10860187^52^ | 110 | 50 (<70)^a^ | <<50% | 1° Pr: 6.5 yr 2° Pr: 10.5 yr | 100% | 100%

1° Pr, primary prevention of retinopathy substudy; 2° Pr, secondary prevention substudy

a Eligibility criteria

3.b Baseline “severity of disease” in studies

Author, Year UI | Mean A_1c_ (Range) | % CVD (Details) | Mean GFR [SCr] (Range) | Albuminuria | % Retinopathy | Other Comorbidities | Mean BMI (Range)
UKPDS trial 1 9742976 9742977 | 7.1% (nd) | nd | [0.92] (0.76–1.1) | Proteinuria 1.9% | 36% | nd | 27.5 (nd)
VA CSDM trial (7 publications) | 9.4% (6.6, nd)^b^ | 38% (13% AMI, 18% angina/CAD, 2% CHF, 7% CVA, 5% TIA, 14% claudication, 5% CABG) | nd | Albuminuria (24 hr): 46%: <30 mg/d 47%: 30–299 mg/d 6%: >299 mg/d Albuminuria (single void): 38%: ACR >0.30) | NPDR: 45% mild 9% moderate PDR 3% mild/moderate | nd | 31.0 (nd)
Shichiri, 2000 10860187 | 9.2% (nd) | nd | nd [<1.5 mg/dL] | All <300 mg/24 hr | 1°Pr: 0% 2°Pr: 100% (simple) | No neuropathy | 20.5 (nd)

1° Pr, primary prevention of retinopathy substudy; 2° Pr, secondary prevention substudy; ACR, albumin/creatinine ratio; NPDR: Non-productive diabetic retinopathy; PDR: Productive diabetic retinopathy

b Eligibility criteria

3.c Study designs

Author, Year UI | Design | Intervention Year(s) | Study Duration | Intervention Goal | Control Goal | Other DM Treatments/Cointerventions
UKPDS trial 1 9742976 9742977 | RCT | 1977–1991 | Mean 10–11.1 yr | Tx: Sulfonylureas or insulin Goal: FBG < 108 mg/dL | Tx: Diet alone, sulfonylureas or insulin if symptomatic Goal: FBG <270 mg/dL | Dietary counseling
VA CSDM trial (7 publications) | RCT | 1990–1993 | Up to 27 mo | Tx: Insulin (≥1x/d) +/− glipizide Goal: HbA1c 4.1–6.0% | Tx: Insulin (1x/d) Goal: HbA1c <13% | No
Shichiri, 2000 10860187 | RCT | <1992–1999 | 8 yr | Tx: Insulin (4x/d) Goals: FBG<140 mg/dL 2h pPr<200 mg/dL HbA1c<7.0% MAGE<100 mg/dL | Tx: Insulin (1–2x/d) Goal: FBG<140 mg/mL | nd

BW, body weight; RCT, randomized controlled trial; nRCT, nonrandomized controlled trial; Cohort (uncontrolled)

Tx, drug treatments; FBG, fasting blood glucose; 2h pPr, 2 hour post-prandial; MAGE, mean amplitude of glycemic excursions

3.d Mortality Results

(All randomized controlled trials)

Author, Year UI | Outcome | N (Tx) | N (Cx) | Effect Magnitude (Control Rate) | P value
UKPDS trial 1 9742976 9742977 | All-cause mortality | 2729 | 1138 | RR=0.54 (0.80–1.10) (Cx: 18.9 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | DM-related death | 2729 | 1138 | RR=0.50 (0.73–1.11) (Cx: 11.5 events/1000 pt-yr) | NS
VA CSDM trial (7 publications) | All-cause mortality | 75 | 78 | 5 vs 5 | NS
Shichiri, 2000 10860187 | Reported deaths | 55 | 55 | 5 vs 7 | nd

Cx:, event rate in control arm; RR, relative risk.

3.e Cardiovascular Events

(All randomized controlled trials)

Author, Year UI | Outcome | N (Tx) | N (Cx) | Effect Magnitude (Control Rate) | P value
UKPDS trial 1 9742976 9742977 | Fatal myocardial infarction | 2729 | 1138 | RR=0.94 (0.68–1.30) (Cx: 8.0 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Non-fatal myocardial infarction | 2729 | 1138 | RR=0.79 (0.58–1.09) (Cx: 9.5 events/1000 pt-yr) | 0.06
UKPDS trial 1 9742976 9742977 | Myocardial infarction (Total) | 2729 | 1138 | RR=0.84 (0.71–1.00) (Cx: 17.4 events/1000 pt-yr) | 0.05
UKPDS trial 1 9742976 9742977 | Fatal sudden death | 2729 | 1138 | RR=0.54 (0.24–1.21) (Cx: 1.6 events/1000 pt-yr) | 0.05
UKPDS trial 1 9742976 9742977 | Heart failure | 2729 | 1138 | RR=0.91 (0.54–1.52) (Cx: 3.3 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Angina | 2729 | 1138 | RR=1.02 (0.71–1.46) (Cx: 17.4 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Fatal stroke | 2729 | 1138 | RR=1.17 (0.54–2.54) (Cx: 1.8 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Non-fatal stroke | 2729 | 1138 | RR=1.07. (0.68–1.69) (Cx: 4.0 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Total stroke | 2729 | 1138 | RR=1.11 (0.81–1.51) (Cx: 5.0 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Death from peripheral vascular disease | 2729 | 1138 | RR=0.26 (0.03–2.77) (Cx: 0.3 events/1000 pt-yr) | NS
VA CSDM trial (7 publications) | All cardiovascular events | 75 | 78 | 35 events (24 pts, Tx) vs 26 events (16 pts, Cx) | NS (Total and for each specific outcome)
Shichiri, 2000 10860187 | All cardiovascular events | 55 | 55 | RD = −0.7 events/100 pt-yr (Cx: 1.3) | nd (implied NS)

Cx:, event rate or change from baseline in control arm; Cx, control arm (usual care); Tx, treatment arm (intensive glycemic control); RD, risk difference; RR, relative risk.

3.f Retinopathy Results

(All randomized controlled trials)

Author, Year UI | Outcome | N (Tx) | N (Cx) | Effect Magnitude (Control Rate) | P value
UKPDS trial 1 9742976 9742977 | Retinal photocoagulation | 2729 | 1138 | RR= 0.71 (0.53–0.96) (Cx: 11.0 events/1000 pt-yr) | 0.003
UKPDS trial 1 9742976 9742977 | Vitreous hemorrhage | 2729 | 1138 | RR= 0.77 (0.28–2.11) (Cx: 0.9 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Blind in one eye | 2729 | 1138 | RR= 0.84 (0.51–1.40) (Cx: 3.5 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Microvascular (includes kidney disease, also in section 3.g) d | 2729 | 1138 | RR= 0.75 (0.60–0.98) (Cx: 11.4 events/1000 pt-yr) | 0.01
VA CSDM trial (7 publications) | Retinopathy progression, baseline to 12 mo | 75 | 78 | RD = +12.1% (Cx: 19.7%) | NS
VA CSDM trial (7 publications) | Retinopathy progression, baseline to 12 mo | 75 | 78 | Δ Retinopathy Levels: Net Δ = +0.30 (Cx: 0.64) | NS
VA CSDM trial (7 publications) | Retinopathy progression, 12 to 24 mo | 75 | 78 | RD = −8.2% (Cx: 18.0%) | NS
VA CSDM trial (7 publications) | Retinopathy progression, baseline to 24 mo | 75 | 78 | RD = +0.5% (Cx: 32.8%) | NS
Shichiri, 2000 10860187 | Retinopathy progression (1° Pr) | 27 | 28 | Risk Reduction: 68% (Cx: 48%, 6.0 events/100 pt-yr) | 0.02
Shichiri, 2000 10860187 | Retinopathy progression (2° Pr) | 28 | 27 | Risk Reduction: 57% (Cx: 56%, 7.0 events/100 pt-yr) | 0.02
Shichiri, 2000 10860187 | Development of preproliferative or proliferative retinopathy (1° Pr) | 27 | 28 | None | nd
Shichiri, 2000 10860187 | Development of preproliferative or proliferative retinopathy (2° Pr) | 28 | 27 | RD = −1.5 events/100 pt-yr (Cx: 3.0) | NS

Cx:, event rate or change from baseline in control arm; C RD, risk difference.

1° Pr, primary prevention of retinopathy substudy; 2° Pr, secondary prevention substudy.

VA CSDM trial: Also, no effect of intensive treatment among the subcohort with some retinopathy at baseline

d retinopathy requiring photocoagulation, vitreous hemorrhage, and/or fatal or nonfatal kidney failure.

3.g Kidney Results

(All randomized controlled trials)

Author, Year UI | Outcome | N (Tx) | N (Cx) | Effect Magnitude (Control Rate) | P value
UKPDS trial 1 9742976 9742977 | Kidney failure | 2729 | 1138 | RR= 0.73 (0.25–2.14) (Cx: 0.8 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Death from kidney failure | 2729 | 1138 | RR= 1.63 (0.21–12.49) (Cx: 0.2 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Microvascular (includes kidney disease, also in section 3.f) d | 2729 | 1138 | RR= 0.75 (0.60–0.98) (Cx: 11.4 events/1000 pt-yr) | 0.01
VA CSDM trial (7 publications) | Progression of microalbuminuria (ACR) | 75 | 78 | Net Δ = −0.095 (Cx: 0.141) | 0.04
Shichiri, 2000 10860187 | Nephropathy progression (1°Pr) | 27 | 28 | Risk Reduction: 74% (Cx: 43.5%, 5.4 events/100 pt-yr) | 0.03
Shichiri, 2000 10860187 | Nephropathy progression (2°Pr) | 28 | 27 | Risk Reduction: 60% (Cx: 40.0%, 5.0 events/100 pt-yr) | 0.04

Cx:, event rate or change from baseline in control arm; RD, risk difference.

ACR, albumin:creatinine ratio from AM urine sample

Shichiri: Progression to albuminuria was seen only in the CIT groups (both primary and secondary prevention)

d retinopathy requiring photocoagulation, vitreous hemorrhage, and/or fatal or nonfatal kidney failure.

3.h Neuropathy Results

(All randomized controlled trials)

Author, Year UI | Outcome | N (Tx) | N (Cx) | Effect Magnitude (Control Rate) | P value
UKPDS trial 1 9742976 9742977 | Amputation | 2729 | 1138 | RR=0.61 (0.28–1.33) (Cx: 1.6 events/1000 pt-yr) | NS
UKPDS trial 1 9742976 9742977 | Amputation or death from PVD | 2729 | 1138 | RR=0.65 (0.38–1.18) (Cx: 1.6 events/1000 pt-yr) | NS
VA CSDM trial (7 publications) | Cranial neuropathy signs & symptoms | 75 | 78 | RD = −69% (Cx: +30%) | NS
VA CSDM trial (7 publications) | Erectile dysfunction | 75 | 78 | RD = +2% (Cx: +20%) | NS
VA CSDM trial (7 publications) | Autonomic neuropathy GI or sweating symptoms | 75 | 78 | No change | NS

Cx:, event rate or change from baseline in control arm; RD, risk difference; RR, relative risk.

LE, lower extremity; UE, upper extremity; GI, gastrointestinal; PVD, peripheral vascular disease

### Study descriptions

Three studies met eligibility criteria evaluating the effect of intensive glycemic control on clinical events in at least 100 patients with type 2 diabetes, with 1 year followup. All three studies were randomized controlled trials of only patients with type 2 diabetes. The UKPDS trial was a very large trial (3,867 participants) with a long follow-up period (approximately 10–11 years), from 1977 to 1991.^12,14^ The other two trials were pilot trials so they were much smaller and followed patients mostly during the 1990s. The VA CSDM trial followed 153 patients for up to 27 months45–51 and Shichiri 2000^52^ followed 110 patients for 8 years. The three trials varied in how many subjects used insulin, from 0 to 100 percent. The UKPDS trial included only patients with newly diagnosed diabetes; their mean HbA1c was substantially lower (mean 7.1%) than the other two trials (approximately 9%).

The three trials used different regimens to achieve intensive glycemic control. The UKPDS and VA CSDM trials set goals of essentially normal glycemia (fasting blood glucose [FBG] < 108 mg/dL and HbA1c between 4.1 and 6.0%, respectively). The Shichiri 2000 study had somewhat looser goals for glycemic control, using a variety of measures.

### Applicability to the Medicare population

The mean age of the patients in the trials ranged from 50 to 60, but a minority of subjects were aged 65 years or older at the beginning of each trial. The maximum ages, per eligibility criteria, at enrollment were 65, 69, and 70 years old. No study performed separate analyses for older patients. As noted, the UKDPDS trials included only patients with newly diagnosed diabetes. The other trials included patients who had had diabetes for approximately a decade. The three trials varied in the prevalence of albuminuria and retinopathy at baseline. The Shichiri 2000 trial also may have reduced applicability to the (American) Medicare population in that it included insulin-using patients with type 2 diabetes who were much more typical of the disease in Japan than in the US. As such, these patients were relatively thin with a mean body mass indices (BMI) of 19.5 to 21.6 kg/m^2^ (depending on the subgroup, overweight is defined as BMI > 25 kg/m^2^).

### Study results

#### Mortality

(Table 3.d)

All three trials reported no significant differences in mortality. The UKPDS trial found nonsignificant trends for decreased all-cause and diabetes-related mortality rates with intensive glycemic control at about 10 years follow-up (relative risk [RR] = 0.54 and 0.50, respectively, in a patient population with underlying death rates of 19 and 11.5 deaths per 1000 patient-years, respectively). The other two trials were small, each with fewer than 100 patients in each arm, and found similar numbers of patients who died, regardless of treatment.

#### Cardiovascular events

(Table 3.e)

All three trials reported results regarding cardiovascular events. The UKPDS trial had sufficient participants to allow analysis of specific events, including cardiac, stroke, and peripheral vascular disease events. The greatest beneficial effects (net reductions) found with intensive glycemic control were for nonfatal (RR = 0.79) and total myocardial infarctions (RR = 0.84); although these effects were of marginal statistical significance (P = 0.06 and 0.05, respectively). A marginally significant reduction in fatal sudden death events was also found (RR = 0.54, P = 0.05); although this event was relatively rare (1.6 events per 1000 patient-years in the conventional treatment arm). No differences were found between intensive and usual glycemic control for other cardiovascular outcomes (i.e., fatal or non-fatal strokes, heart failure, angina, fatal MI, deaths from peripheral vascular disease). The other two trials found no significant differences for all cardiovascular events, although the VA CSDM trial found that more patients using intensive glycemic control had cardiovascular events.

#### Retinopathy

(Table 3.f)

All three trials reported retinopathy-related outcomes. Shichiri 2000, though, was the only trial that was designed primarily to evaluate retinopathy. They found that among both patients receiving the intervention for primary prevention (no retinopathy at baseline) and for secondary prevention (simple retinopathy at baseline) intensive glycemic control resulted in substantial reductions in progression of retinopathy after 8 years (risk reduction = 68 and 57 percent, respectively; P = 0.02, both). However, no significant differences were found in development of preproliferative or proliferative retinopathy in either group. No patient without retinopathy at baseline developed preproliferative or proliferative retinopathy. However, development of nonproliferative retinopathy, though rare, was less common in the intensive control arm (1.5 vs. 3.0 percent).

The UKPDS trial found a significant net reduction in the need for retinal photocoagulation after about 10 years with intensive glycemic control (RR = 0.71, P = 0.003), but no significant differences in vitreous hemorrhage or blindness events. However, combining all microvascular events (due to retinopathy and kidney failure), a substantial and statistically significant reduction was found (RR = 0.75, P = 0.01) The VA CSDM trial found an interesting pattern in retinopathy progression during the first two years of follow-up. Patients receiving intensive glycemic control were more likely to have retinopathy progression during the first 12 months, but then less likely to have continued progression during the next 12 months, such that at 24 months, the rates of progression were nearly identical. However, none of these trends was statistically significant.

None of the studies reported on improvement in levels of retinopathy among patients on intensive glycemic control.

#### Kidney events

(Table 3.g)

UKPDS found no statistically significant difference in rates of kidney failure after about 10 years between interventions (although, as noted above, a significant reduction in all microvascular events was found). No study reported on kidney function (e.g., serum creatinine or glomerular filtration rate). The VA CSDM trial found significantly slower progression of microalbuminuria at 2 years, and Shichiri 2000 found risk reductions of 74 and 60 percent in progression of nephropathy at 8 years in patients with either no retinopathy or simple retinopathy, respectively, at baseline. None of the studies reported on improvement in levels of kidney function among patients on intensive glycemic control.

#### Neuropathy events

(Table 3.h)

No statistically significant differences were reported in a wide range of neuropathy events either in the UKPDS or the VA CSDM trial.

### Conclusions

Three randomized controlled trials met inclusion criteria for this report. All included only a minority of patients age 65 years or older at study baseline and the largest trial, UKPDS, included very few patients age 65 years at baseline. The applicability of the UKPDS trial to the Medicare population is further hampered by their eligibility criteria, such that only those with newly diagnosed diabetes were enrolled; probably for this reason, the patients’ level of glycemia at baseline was relatively low. Shichiri 2000 may also be of limited applicability to the US Medicare population as this Japanese study included relatively thin, insulin-requiring patients while the typical patient with type 2 diabetes in the US is overweight and is not treated with insulin.

Overall, these three trials do not provide consistent, adequate evidence on clinical benefits from intensive glycemic control for mortality, cardiovascular events, kidney failure, or severe neuropathy-related events; although beneficial trends were found for myocardial infraction and sudden deaths in the UKPDS trial. Notably, these studies were not designed to find statistically significant effects on these clinical outcomes. Regarding retinopathy, the UKPDS trial found a significant reduction in need for photocoagulation, but not vitreous hemorrhage or blindness; the VA CSDM trial found no significant effect on retinopathy progression; but Shichiri 2000, which was specifically designed to address retinopathy outcomes and included a different population of patients, found large, statistically significant reductions in progression of retinopathy, but not of development of preproliferative or proliferative retinopathy. The studies do not provide evidence for any improvements in retinopathy or kidney function with intensive glycemic control.

## Intensive glycemic control and risk of severe hypoglycemia in patients with type 2 diabetes

(Table 4)

Table 4 Studies of intensive glycemic control and hypoglycemia

4.a Applicability of “large” prospective studies to non-dialysis-dependent Medicare population (baseline data)

Author, Year UI | N | Mean Age (Range) | ~%≥65 yr | Mean Duration DM | % DM 2 | % Using Insulin
Randomized controlled trials
UKPDS trial 1 9742976^12^ 9742977^14^ | 3867 | 53 (25–65)^a^ | ~0% | “Newly diagnosed” | 100% | 0%
UKPDS trial 2 b 10388978^53^ 11815505^54^ | 826 | 52 (25–65)^a^ | ~0% | “Newly diagnosed” | 100% | 0%
Van der Does, 1988 9839098^55^ | 176 | 64 (40–75)^a^ | ~50% | 4.0 yr | 100% | 26%
VA CSDM trial (7 publications) 45–51 | 153 | 60 (40–69)^a^ | <50% | 7.9 yr (all<15 yr) | 100% | 59%
Shichiri, 2000 10860187^52^ | 110 | 50 (<70)^a^ | <50% | 1°Pr: 6.5 yr 2°Pr: 10.5 yr | 100% | 100%
Nonrandomized controlled study
de Sonnaville, 1997 9389427^56^ | 350 | 66 (nd) | ~50% | 6.4 yr | 100% | 4%
Prospective cohort
Albisser, 2001 11911169^59^ | 978 | 58 (19–81) | <50% | nd | nd | nd
Goddijn, 1999 10229289^57^ | 94 | nd (31–83) | nd | 8.5 yr | 100% | 0%
Saudek, 1996 8861991^58^ | 62 | 56 (40–69) | <50% | 8.8 yr | 100% | 100%

a Eligibility criteria

b With the realization that progressive hyperglycemia was occurring in all randomized groups in UKPDS Study 1 and that additional therapy might be desirable at the stage of sulfonylurea inadequacy rather than sulfonylurea failure, a modified protocol (Glucose Study 2) was introduced in the last 8 UKPDS centers. This protocol, the aim of which was to determine whether a more aggressive glucose control policy could minimize hyperglycemic progression, differed only in that insulin therapy was added immediately inpatients allocated to sulfonylurea therapy if maximal doses did not maintain FPG level <108 mg/dl (6 mmol/L).

4.b Baseline “severity of disease” in studies

Author, Year UI | Mean A_1c_ (Range) | % CVD (Details) | Mean GFR [SCr] (Range) | Albuminuria | % Retinopathy | Other Comorbidities | Mean BMI (Range)
Randomized controlled trials
UKPDS trial 1 9742976 9742977 | 7.1 (nd) | nd | [0.92] (0.76–1.1) | Proteinuria 1.9% | 36% | nd | 27.5 (nd)
UKPDS trial 2 10388978 11815505 | 6.9 (6.1–8.0) | nd | nd [≤2.0] c | nd | nd | nd | 28.8 (nd)
Van der Does, 1988 9839098 | 7.5 | 21% | nd | nd | nd | 8% hypoglycemia (grade 2) | 28
VA CSDM trial (7 publications) | 9.4 (6.6, nd)1 | 38% (13% AMI, 18% angina/CAD, 2% CHF, 7% CVA, 5% TIA, 14% claudication, 5% CABG) | nd | Albuminuria (24 hr): 46%: <30 mg/d 47%: 30–299 mg/d 6%: >299 mg/d Albuminuria (single void): 38%: ACR >0.30) | NPDR: 45% mild 9% moderate PDR 3% mild/moderate | nd | 31.0 (nd)
Shichiri, 2000 10860187 | 9.2 (nd) | nd | nd [<1.5] | All <300 mg/24 hr | 1°Pr: 0% 2°Pr: 100% (simple) | No neuropathy | 20.5 (nd)
Nonrandomized controlled study
de Sonnaville, 1997 9389427 | 7.5 (nd) | nd | nd | nd | nd | nd | Men ~27 Women ~28.5 (nd)
Prospective cohort studies
Albisser, 2001 11911169 | 8.8 | nd | nd | nd | nd | nd | nd
Goddijn, 1999 10229289 | 10.4 (nd) | nd | nd | nd | nd | ND | 27.6 (nd)
Saudek, 1996 8861991 | 8.9 | nd | nd | nd | nd | nd | 31.3

1° Pr, primary prevention of retinopathy substudy; 2° Pr, secondary prevention substudy; ACR, albumin/creatinine ratio; NPDR: Non-productive diabetic retinopathy; PDR: Productive diabetic retinopathy

c Eligibility criteria

4.c Study designs

Author, Year UI | Design | Intervention Year(s) | Study Duration | Intervention Goal | Control Goal | Other DM Treatments/Cointerventions
Randomized controlled trials
UKPDS trial 1 9742976 9742977 | RCT | 1977–1991 | Mean 10–11.1 yr | Tx: Sulfonylureas or insulin Goal: FBG < 108 mg/dL | Tx: Diet alone, sulfonylureas or insulin if symptomatic Goal: FBG <270 mg/dL | Dietary counseling
UKPDS trial 2 10388978 11815505 | RCT | 1987–1991 | 6 yr | Tx: Sulfonylureas or insulin Goal: FBG < 108 mg/dL | Tx: Diet alone, sulfonylureas or insulin if symptomatic Goal: FBG <270 mg/dL | Dietary counseling
Van der Does, 1988 9839098 | RCT | 1992–1994 | 1 yr | Tx: Metformin, sulfonylureas or insulin Goal: FBG < 117.1 mg/dL | Tx: Metformin, sulfonylureas or insulin Goal: FBG < 153.1 mg/dL | nd
VA CSDM trial (7 publications) | RCT | 1990–1993 | Up to 27 mo | Tx: Insulin (≥1x/d) +/− glipizide Goal: HbA1c 4.1–6.0% | Tx: Insulin (1x/d) Goal: HbA1c <13% | No
Shichiri, 2000 10860187 | RCT | <1992–1999 | 8 yr | Tx: Insulin (4x/d) Goals: FBG<140 mg/dL 2hPG<200 mg/dL HbA1c<7.0% MAGE<100 mg/dL | Tx: Insulin (1–2x/d) Goal: FBG<140 mg/mL | nd
Nonrandomized controlled study
de Sonnaville, 1997 9389427 | nRCT | 1992 | 2 yr | Tx: Sulfonylureas, metformin, insulin Goal: FBG<117.1 mg/dL | Tx: Sulfonylureas, metformin, insulin Goal: FBG<153.1 mg/dL | nd
Prospective cohort studies
Albisser, 2001 11911169 | Prospective cohort | <2001 | 1 yr | Tx: Training (nd drugs) Goal: pPG=140 mg/dL (implied) | nd
Albisser, 2001 11911169 | Prospective cohort | <2001 | 1 yr | Tx: Computer (nd drugs) Goal: pPG=140 mg/dL | nd
Albisser, 2001 11911169 | Prospective cohort | <2001 | 1 yr | Tx: Education (nd drugs) Goal: pPG=”as close to normal as possible” | nd
Goddijn, 1999 10229289 | Prospective cohort | <1999 | 1 yr | Tx: Insulin and oral drugs Goal: HbA1c<8% | nd
Saudek, 1996 8861991 | Prospective cohort | <1996 | 1 yr | Tx: Multidose insulin Goal: FBG<130 mg/dL; RBG 80–115 | Diet | Exercise
Saudek, 1996 8861991 | Prospective cohort | <1996 | 1 yr | Tx: Implantable insulin pump Goal: FBG<130 mg/dL; RBG 80–115 | Diet | Exercise

pPG, preprandial glucose; Tx, drug treatments; FBG, fasting blood glucose; RBG, random blood glucose; 2hPG, 2-hour post-prandial glucose; MAGE, mean amplitude of glycemic excursions

4.d Study Results

Author, Year UI | Outcome (Definition) | N (Tx) | N (Cx) | Effect Magnitude | P Value
Randomized controlled trials
UKPDS trial 1 9742976 9742977 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 2729 | 1138 | Proportion of patients with ≥1 major, or any, hypoglycemic episode in a year was significantly higher for intensive treatment group than for conventional treatment group d (Rates per 100 pt-yr were not reported) | <0.05
UKPDS trial 1 9742976 9742977 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 2729 | 1138 | Diet or conventional treatment 0.7% | nd
UKPDS trial 1 9742976 9742977 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 2729 | 1138 | Chlorpropamide | nd
UKPDS trial 1 9742976 9742977 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 2729 | 1138 | Glibenclamide | nd
UKPDS trial 1 9742976 9742977 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 2729 | 1138 | Insulin 1.8% | nd
UKPDS trial 2 10388978 11815505 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 584 e | 242 | Conventional Rx: 0 (Rates per 100 pt-yr were not reported)
UKPDS trial 2 10388978 11815505 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 584 e | 242 | Intensive Rx Insulin alone: 1.0% 3.4% (95% CI 2.2–4.5) | nd
UKPDS trial 2 10388978 11815505 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 584 e | 242 | Sulfonylurea (±insulin): 1.6% (95% CI 0.9–2.2) | nd
UKPDS trial 2 10388978 11815505 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 584 e | 242 | Chlorpropamide (±insulin): 1.8% (95% CI 0.8–2.7) | nd
UKPDS trial 2 10388978 11815505 | Major hypoglycemic episodes, per year (if 3rd-party help or medical intervention necessary) | 584 e | 242 | Glipizide (±insulin): 1.4% (95% CI 0.6–2.2) | nd
Van der Does, 1988 9839098 | Hypoglycemic events Grade 3 (help from others necessary) | 174 | | 1.4% 0 events
VA CSDM trial (7 publications) | Severe hypoglycemia (help from others necessary) | 75 | 78 | 5 events (in 5 pts) vs 2 events (in 2 pts) or 0.03/pt/yr vs 0.01/pt/yr | NS
Shichiri, 2000 10860187 | Severe hypoglycemia (help from others necessary, BG <50 mg/dL, prompt recovery after glucose loading) | 55 | 55 | 0 events
Nonrandomized controlled study
de Sonnaville, 1997 9389427 | Hypoglycemia Grade 3 (required oral carbohydrates with help of others) | 350 | 68 | 4 times in 2 yr for those on sulfonylureas vs No episodes reported | nd
de Sonnaville, 1997 9389427 | Hypoglycemia Grade 4 (hypoglycemic coma) | 350 | 68 | 13 episodes of suspected coma (3 events of cardiac arrhythmia, 1 event of transient ischemic attack, and 9 events by 7 insulin-treated patients) vs. No episodes reported | nd
Prospective cohort studies
Albisser, 2001 11911169 | Severe hypoglycemic events (not defined)
Albisser, 2001 11911169 | Training | 589 | | 0 events
Albisser, 2001 11911169 | Computer | 238 | | 0 events
Albisser, 2001 11911169 | Education | 151 | | 0 events
Goddijn, 1999 10229289 | Hypoglycemia (needing assistance) | 94 | | 0 events
Saudek, 1996 8861991 | Definite severe hypoglycemia (not defined) | 59 (MDI) | | 0.98 events/100 pt-yr
Saudek, 1996 8861991 | Definite severe hypoglycemia (not defined) | 62 (IIP) | | 7.85 events/100 pt-yr

BG, blood glucose; MDI, multidose insulin; IIP, implantable insulin pump;

d Annual data also graphically reported. During first 10 years, the rates of “major episodes” remains stable. Beyond 10 years, the rates appear to rise, but the numbers of subjects analyzed diminish rapidly (Figure 9^12^ and Figure 4^14^ in original articles).

e Of the 826 patients whose fasting plasma glucose was between 108 to 270 mg/dL were randomized, 242 were assigned conventional glucose control policy, and 584 were assigned intensive glucose control policy (in which 245 with insulin alone, 339 with sulfonylurea and insulin).

### Study descriptions

There were nine studies identified that met our inclusion criteria including any prospective study design, type 2 diabetes, sample size of at least 50 patients, and study duration of 3 months follow-up or more. We examined the effects of intensive glycemic control on major or severe hypoglycemia events. The nine studies included five randomized controlled trials (in 13 included articles),12,14,45–55 one non-randomized comparison,56 and three prospective cohort studies.57–59 The sample sizes ranged from 62 to 3,867 subjects. UKPDS trial 1, the largest trial, followed newly diagnosed patients for mean of 10–11.2 years. The 3 prospective cohort studies and one of the randomized trials followed the patients for 1 year each. Studies varied widely in the percentage of patients using insulin, and thus possibly in levels of native insulin and glucose disposal. Interventions included step-up insulin regimens or multidose insulin alone, or in combination with other interventions such as diet, oral hypoglycemic agents, exercise, education, computer-assisted care, self-monitoring, or monitoring by healthcare providers. FBG goals for intensive glycemic control ranged from <108 to <140 mg/dL.

### Applicability to the Medicare population

The mean age of the subjects ranged from 52 to 66 years. Three studies had over 50 percent of the patients older than 65 years (van der Does 1998, Albisser 2001, and de Sonnnaville 1997), and in Goddijn 1999, the patient population ranged from 31 to 83 years. Two of the larger studies (UKPDS trials 1 and 2) had no patients over the age of 65. No study performed separate analyses for older patients. All of the studies reported populations to have type 2 diabetes except Albisser 2001, which probably also included patients with type 1 diabetes. Most of the subjects were overweight with the studies reporting mean body mass index ranging from 27 to 31.3, except for the Japanese study Shichiri 2000, which reported a mean body mass index of 20.5 kg/m^2^. The mean HbA1c reported ranged from 6.9% to 10.4%. Prevalence of cardiovascular disease, kidney disease, and retinopathy were rarely reported.

### Study results

The largest trial, UKPDS trial 1, reported that significantly more patients being treated with intensive glycemic control had at least one major (or any) hypoglycemic episodes a year than patients on conventional treatment; although the exact numbers for this comparison were not reported. However, data regarding what treatments patients were receiving (regardless of glycemic goal of treatment) indicate that between approximately 1 and 2 percent of patients had major hypoglycemic events during the first 10 years of treatment. In the follow-up trial (UKPDS trial 2), between 1.4 and 3.4 percent of patients annually receiving different antidiabetic treatments for intensive glycemic control reported major hypoglycemic episodes, compared to no such episodes for patients receiving conventional treatment; however, no statistical analysis was reported comparing the two groups. These studies did not analyze the frequency of events, per se, but only the percentage of patients suffering events. The remaining three, relatively small trials, reported no or very few severe hypoglycemic events, with no difference between the two interventions. Similarly, the nonrandomized comparative study (de Sonnaville 1997) reported grade 3 and 4 hypoglycemia only among patients receiving intensive glycemic control.

Among the three studies without usual care arms, two reported no severe hypoglycemic events. These two studies (Albisser 2001 and Goddijn 1999) may have been the most recently conducted studies (prior to 2001 and 1999, respectively, although the exact study dates were not reported). The third uncontrolled study, Saudek 1996, was a randomized trial comparing traditional multidose insulin and implanted insulin pumps. In both arms, patients received intensive glycemic control. With multidose insulin, severe hypoglycemia occurred at a similar rate as in the UKPDS trials; however, substantially more patient with an implanted insulin pump had severe hypoglycemia episodes.

### Conclusions

Nine studies met the inclusion criteria for this report. Eight studies explicitly included only patients with type 2 diabetes and three studies had mean ages above 65 years old. The two UKPDS trials and the nonrandomized controlled study, all relatively large, provide evidence that severe hypoglycemic episodes are significantly (or at least substantially) more common among patients being treated with intensive glycemic control. It is unclear whether the lack of difference in effect of the other comparative trials was due to between-study differences or to an insufficient number of subjects to detect possible differences. However, it is notable, that the two studies (possibly) conducted most recently both report no episodes of severe hypoglycemic episodes among a large number of subjects. This raises the possibility that with more recent treatment protocols or training methods, that the risk of severe hypoglycemic episodes is very low.

In contrast with the relatively small percentage of patients with type 2 diabetes with severe hypoglycemic episodes (less than 2 percent, or fewer than 1 episode per 100 patient-years), in DCCT (among patients with type 1 diabetes), with intensive therapy, there were 62 severe hypoglycemic episodes per 100 patient-years compared with 19 such episodes per 100 patient-years in the conventional-therapy group.60

## Correlation of intensive glycemic control with outcomes in patients with type 2 diabetes

### Study descriptions

Five of the studies on intensive glycemic control in patients with type 2 diabetes reported on analyses correlating level of glycemic control with clinical outcomes of interest (in six articles).47,49,52,53,55,57 All three studies reporting clinical outcomes (UKPDS, VA CSDM, and Shichiri 2000) also evaluated the correlation. Two of these and two other studies also evaluated the correlation of achieved HbA1c with frequency of hypoglycemia episodes (UKPDS, VA CSDM, van der Does 1998, and Goddijn 1999). Overall, these studies had fair applicability to the Medicare population (details have been given in the previous sections).

### Clinical events

(Table 5)

Table 5 Correlation of glycemic control and clinical outcomes

Author, Year UI | N (% events) | | Study Duration | Predictor | Statistical Method | Outcome | | Effect | P-value
Author, Year UI | Tx | Cx | Study Duration | Predictor | Statistical Method | Outcome | | Effect | P-value
UKPDS trial 1 10388978^53^ | 3104 (1.7% micro) (2.0% macro) | | Mean 10–11.1 yr | HbA1c (%) | t test | | | [underlined: HbA1c] | 0.0007
UKPDS trial 1 10388978^53^ | 3104 (1.7% micro) (2.0% macro) | | Mean 10–11.1 yr | HbA1c (%) | t test | Microvascular complications^a^ | + | 9.6% | 0.0007
UKPDS trial 1 10388978^53^ | 3104 (1.7% micro) (2.0% macro) | | Mean 10–11.1 yr | HbA1c (%) | t test | Microvascular complications^a^ | − | 8.3% | 0.0007
UKPDS trial 1 10388978^53^ | 3104 (1.7% micro) (2.0% macro) | | Mean 10–11.1 yr | HbA1c (%) | t test | Macrovascular complications b | + | 8.3% | NS
UKPDS trial 1 10388978^53^ | 3104 (1.7% micro) (2.0% macro) | | Mean 10–11.1 yr | HbA1c (%) | t test | Macrovascular complications b | − | 8.3% | NS
VA CSDM trial 9009975^49^ | 75 (32%) | 78 (21%) | Up to 27 mo | HbA1c (1% increase) | Univariate Cox | Clinical CVD events | | RR=0.84 (95% CI 0.68, 1.03) | 0.10
VA CSDM trial 9009975^49^ | 75 (32%) | 78 (21%) | Up to 27 mo | HbA1c (1% increase) | Multivariate Cox | Clinical CVD events | | RR=0.81 (95% CI 0.55, 1.01) | 0.06
Shichiri, 2000 10860187^52^ (See study Figure 5) | 55 (20% retinop) (14% neph) | 55 (52% retinop) (42% neph) | 8 yr | HbA1c (%) | Regression | Rate of worsening of Retinopathy | | Continuously increasing risk | nd
Shichiri, 2000 10860187^52^ (See study Figure 5) | 55 (20% retinop) (14% neph) | 55 (52% retinop) (42% neph) | 8 yr | FBG (mg/dL) | Regression | Rate of worsening of Retinopathy | | Continuously increasing risk | nd
Shichiri, 2000 10860187^52^ (See study Figure 5) | 55 (20% retinop) (14% neph) | 55 (52% retinop) (42% neph) | 8 yr | 2hPG (mg/dL) | Regression | Rate of worsening of Retinopathy | | Continuously increasing risk | nd
Shichiri, 2000 10860187^52^ (See study Figure 5) | 55 (20% retinop) (14% neph) | 55 (52% retinop) (42% neph) | 8 yr | HbA1c (%) | Regression | Rate of worsening of Nephropathy | | Continuously increasing risk | nd
Shichiri, 2000 10860187^52^ (See study Figure 5) | 55 (20% retinop) (14% neph) | 55 (52% retinop) (42% neph) | 8 yr | FBG (mg/dL) | Regression | Rate of worsening of Nephropathy | | Continuously increasing risk | nd
Shichiri, 2000 10860187^52^ (See study Figure 5) | 55 (20% retinop) (14% neph) | 55 (52% retinop) (42% neph) | 8 yr | 2hPG (mg/dL) | Regression | Rate of worsening of Nephropathy | | Continuously increasing risk | nd

CI, confidence interval; 2hPG, 2 hour post-prandial glucose; retinop, retinopathy progression; neph, nephropathy progression.

a Retinal photocoagulation, vitreous hemorrhage, or renal failure

b Nonfatal myocardial infarction, angina, heart failure, stroke

#### Study results

The authors of the UKPDS trial combined all patients from all trial arms for their analyses. They found that patients with microvascular complications (retinal photocoagulation, vitreous hemorrhage, or kidney failure) achieved significantly higher HbA1c than those without complications; however, no difference in HbA1c was found among those with and without macrovascular complications (nonfatal myocardial infarction, angina, heart failure, stroke). Notably, though, in this trial of newly diagnosed patients with diabetes, only about 2 percent of patients developed either micro- or macrovascular complications over about 10 years of treatment.

Similarly Shichiri 2000 found continuously increasing rates of both retinopathy and nephropathy with higher levels of achieved HbA1c, fasting blood glucose (FBG), or 2-hour post-prandial glucose (See original article’s Figure 5^52^). This Japanese study of normal-weight patients was relatively small; though patients were followed for 8 years and had high rates of both clinical outcomes.

In contrast, one publication of the VA CSDM trial found that by both univariate and multivariate Cox regression, after about 2 years of treatment, there was a borderline trend (P = 0.10 and 0.06, respectively) of higher HbA1c associated with lower risk of time to cardiovascular event. They reported that the trend was almost entirely attributable to patients assigned to the intensive glycemic control arm.42

#### Conclusions

Two long-term studies, one of newly diagnosed patients with type 2 diabetes, one of patients with long-standing disease, found that lower achieved HbA1c, primarily via intensive glycemic control, correlated with lower rates of microvascular complications (retinopathy and nephropathy, both studies) and macrovascular complications (cardiovascular events, one study). One of these studies provided evidence of a continuous increase in microvascular complications with increasingly poor glycemic control over a wide range of glycemia.

While the VA CSDM study found a trend toward a correlation between better glycemic control and increased rate of cardiovascular events in the first 2 years of intervention, the authors suggest caution in interpreting these results and compare them to the transiently worsened retinopathy found with intensive glycemic control in studies of insulin-dependent diabetes (and also found after 12 months within the same study).

Overall, there is evidence to suggest a long-term reduction in micro- and macrovascular events with improved glycemic control within these studies; however, it may be the case that a transient increase in cardiovascular events may occur with the introduction of intensive glycemic control.

### Hypoglycemia

(Table 6)

Table 6 Correlation of glycemic control and hypoglycemia

Author, Year UI | N (% events) | | Study Duration | Predictor | Statistical Method | Outcome | | Effect | P-value
Author, Year UI | Tx | Cx | Study Duration | Predictor | Statistical Method | Outcome | | Effect | P-value
UKPDS trial 1 10388978^53^ | 1121, on insulin (50%) | | Mean 10–11.1 yr | HbA1c (%) | t test | | | [underlined: HbA1c] | NS
UKPDS trial 1 10388978^53^ | 1121, on insulin (50%) | | Mean 10–11.1 yr | HbA1c (%) | t test | Report of hypoglycemia (?severity) at office visits (# reports) | 0 | 8.6% | NS
UKPDS trial 1 10388978^53^ | 1121, on insulin (50%) | | Mean 10–11.1 yr | HbA1c (%) | t test | Report of hypoglycemia (?severity) at office visits (# reports) | 1 | 8.4% | NS
UKPDS trial 1 10388978^53^ | 1121, on insulin (50%) | | Mean 10–11.1 yr | HbA1c (%) | t test | Report of hypoglycemia (?severity) at office visits (# reports) | 2+ | 8.6% | NS
Van der Does, 1988 9839098^55^ | 174 (7.5%) | | 1 yr | HbA1c decrease ≥1.0% vs. <1.0% | ?t test | Grade 2 hypoglycemia | | 9.5% (≥1%) vs. 6.8% (<1%) had events | NS (implied)
VA CSDM trial 9571345^47^ | 75 | 78 | Up to 27 mo | HbA1c (0.5% decrease) | Qualitative | Non-severe or severe hypoglycemia events | | “After the initial mean HbA1c fell in phase I to 7.8% with relatively few hypoglycemic events, each additional 0.5% fall of HbA1c caused a doubling of the reported number of reactions”
VA CSDM trial 9571345^47^ | (mean ~6.5 episodes in 3 months) | | Up to 27 mo | HbA1c (0.5% decrease) | Qualitative | Non-severe or severe hypoglycemia events | | “After the initial mean HbA1c fell in phase I to 7.8% with relatively few hypoglycemic events, each additional 0.5% fall of HbA1c caused a doubling of the reported number of reactions”
Goddijn, 1999 10229289^57^ | 94 (19%) | -- | 1 yr | Achieved HbA1c≤8% vs. >8% | t test | Change in “hypoglycemia complaints” | | +14% (≤8%) vs. +10.8% (>8%) | NS

#### Study results

Across the four studies that reported a correlation between either achieved HbA1c or change in HbA1c and hypoglycemia outcomes, each used a different definition of hypoglycemia were used and performed a unique analysis. No study evaluated only the rate of grade 3 or greater hypoglycemia. Only van der Does 1998 was unambiguous about what level of severity of hypoglycemia was being analyzed.

The largest study with the longest duration of follow-up, UKPDS, found no difference in mean HbA1c among patients who reported hypoglycemia events and those that did not. Two smaller, 1 year studies (van der Does 1998 and Goddijn 1999) both found that higher percentages of patients whose glycemia was more tightly controlled had hypoglycemia episodes, but neither finding was statistically significant. The VA CSDM trial reported that “After the initial mean HbA1c fell in phase I to 7.8% with relatively few hypoglycemic events, each additional 0.5% fall of HbA1c caused a doubling of the reported number of reactions.” However, no further details or statistical analysis was reported.

#### Conclusions

While one study suggests an exponential increase in hypoglycemia episodes with continually decreasing HbA1c below approximately 8%, overall the evidence weakly suggests only a possible correlation between tightness of glycemic control and frequency of hypoglycemia episodes. Importantly, none of the reviewed studies that analyzed correlations evaluated the outcome of interest, grade 3 or higher episodes of hypoglycemia. Furthermore, it is unclear how the findings from clinical trials, generally with strict protocols and intensive clinical monitoring, would translate into typical clinical environment.

## Self-monitored blood glucose and glycemic control (HbA1c) in patients with type 2 diabetes

### Randomized trials

(Table 7)

Table 7 Randomized controlled trials of self monitoring of blood glucose levels and glycemic control

7.a Applicability of “large” randomized controlled trials to non-dialysis-dependent Medicare population (baseline data)

Author, Year UI | N | Mean Age (Range) | ~%≥65 yr | Mean Duration DM | % DM 2 | % Using Insulin
Guerci, 2003 14707887^61^ | 689 | 62 (40–75)^a^ | <50% | 8.0 yr | 100% | 0%
Schwedes, 2002 12401734^64^ | 223 | 60 (45–70)^a^ | <50% | 5.3 yr | 100% | 0%
Fontbonne, 1989 2630378^62^ | 110 | 55 (nd) | <50% | 12.5 yr (≥3 yr)^a^ | 100% | 0%
Davidson, 2005 15808142^63^ | 88 | 50 (nd) | <<50% | 5.6 yr | 100% | 0%
Kibriya, 1999 10624792^65^ | 64 | 50 (35–65) | ~0% | nd | 100% | nd

a Eligibility criteria

7.b Baseline “severity of disease” in studies

Author, Year UI | Mean A_1c_ (Range) | % CVD (Details) | Mean GFR [SCr] (Range) | Albuminuria | Retinopathy (Details) | Other Comorbidities | Mean BMI (Range)
Guerci, 2003 14707887 | 9.0 (7.5–11.0)^a^ | nd | nd | nd | nd | nd | 30.0 (nd)
Schwedes, 2002 12401734 | 8.4 (7.5–10.0)^a^ | nd | nd | nd | nd | nd | 31.4 (>25)^a^
Fontbonne, 1989 2630378 | 8.2 (nd) | nd | nd | nd | nd | nd | 27.1 (nd)
Davidson, 2005 15808142 | 8.4 (nd) | nd | nd | nd | nd | nd | 32.2 (nd)
Kibriya, 1999 10624792 | 7.9 (nd) | nd | nd | nd | 0 | nd | 23.9 (nd)

a Eligibility criteria

7.c Study designs

Author, Year UI | Design | Intervention Year(s) | Study Duration | Intervention (Frequency) | Control | Other DM Treatments/Cointerventions
Guerci, 2003 14707887 | RCT | <2003 | 24 wk | SMBG (≥6x/wk) Did not report training on how to respond to readings | No SMBG | 99.5% on oral antidiabetic agents ~80% on fibrates, ACEI, or HMG-CoA reductase inhibitors
Schwedes, 2002 12401734 | RCT | <2002 | 24 wk | SMBG (6x/d on 2 d/wk) Did not report training on how to respond to readings | No SMBG | Diet alone +/− sulfonylurea or metformin
Fontbonne, 1989 2630378 | RCT | <1989 | 6 mo | SBGM (2x/d every other day; 3x/d on Saturdays) Did not report training on how to respond to readings | No SMBG | Dietary intervention and/or oral antidiabetic agents
Davidson, 2005 15808142 | RCT | <2005 | 6 mo | SMBG (6x/d; 6 d/wk) Did not report training on how to respond to readings | No SMBG | Metformin, sulfonylurea, and/or thiazolidinedione
Kibriya, 1999 10624792 | RCT | <1999 | 18 mo | SMBG (2–3x/d every 2 wk) Medications adjusted based on SMBG readings, as necessary | No SMBG | Oral hypoglycemic agents or insulin

ACEI: Angiotensin converting enzyme inhibitors; d: day(s); mo: month(s); RCT: Randomized controlled trial; SMBG: Self monitoring of blood glucose; wk: week(s)

7.d Glycemic Control Results

Author, Year UI | Outcome | N (Tx) | N (Cx) | Effect Magnitude (Change in Control Group) | P value
Guerci, 2003 14707887 | Δ HbA1c | 345 | 344 | Net Δ = −0.28% (Cx: −0.60%) | 0.009
Schwedes, 2002 12401734 | Δ HbA1c | 113 | 110 | Net Δ = −0.46% (95% CI −0.77, −0.11) (Cx: −0.54%) | 0.009
Fontbonne, 1989 2630378 | Δ HbA1c | 56 | 54 | Net Δ = +0.14% (Cx: −0.50) | nd
Davidson, 2005 15808142 | Δ HbA1c | 43 | 45 | Net Δ = −0.2% (95% CI: −1.1, 0.6%) (Cx: −0.6%) | NS
Kibriya, 1999 10624792 | Δ HbA1c | 32 | 32 | Net Δ = −0.99% (Cx: −0.38%) | nd (Tx: P=0.02 Cx: NS compared to baseline)

95% CI, 95% confidence interval; Cx, control arm (usual care); Tx, treatment arm (intensive glycemic control).

#### Study descriptions

We identified five randomized trials meeting our inclusion criteria (Guerci 2003, Schwedes 2002, Fontbonne 1989, Davidson 2005, Kibriya 1999).61–65 We included all prospective studies with a minimum sample size of 50 subjects and a minimum duration of follow-up of 6 months. Their sample size ranged from 64 to 689 patients; four included more than 100 patients. The trials were published between 1989 and 2005.

The frequency of glucose monitoring in the experimental arms was highly variable, ranging from 2–3 daily measurements every two weeks to six measurements per day (on average). Similarly, the duration of the intervention was 6 months in four trials and more than a year in two trials (approximately 15 and 18 months). Only Kibriya 1999 reports advising the patients how to act based on SMBG measurements, whereas the other studies do not mention any relevant information. None of the studies fully described how the use of SMBG was incorporated into an overall diabetes management plan. The comparator management plan was absence of self-monitoring in all trials. One trial (Fontbonne 1989) was completed before the 1990s, whereas all other studies were estimated to have been completed later than 1997, when the latest amendments to the diagnostic criteria for diabetes were made. In all trials, patients in both arms received concomitant treatment. In one trial, patients were on insulin or oral agents (Kibriya 1999) during the intervention. Schwedes 2002 and Fontbonne 1989 reported that a dietary intervention was used with or without oral antidiabetic drugs. In the remaining two trials, patients received oral antidiabetic drugs (Guerci 2003 and Davidson 2005).

#### Applicability to the Medicare population

The mean age of the participants ranged from 50 years to 62 years. Thus, in all studies the estimated proportion of patients who were older than 65 years is less than half; in two studies it was probably less than a quarter of the assessed patients (Kibriya 1999 and Davidson 2005). No study performed separate analyses for older patients. The average duration of diabetes was more than 5 years in the four trials that reported the pertinent information, and was over 10 years only in Fontbonne 1989. All trials included patients with type 2 diabetes only. In the remaining trials, none of the participants was on insulin before entering the trial (with the possible exception of Kibriya 1999, where the pertinent information was not mentioned).

The included trials did not report information about the presence of cardiovascular disease, kidney disease, retinopathy, or other comorbidities in the enrolled patients. The average BMI of the studied populations was over 25 kg/m^2^ (the boundary for overweight) in all but Kibriya 1999; thus, in five trials more than half (all in Schwedes 2002) of the subjects were overweight. In three trials (Guerci 2003, Schwedes 2002, Davidson 2005), it is estimated that half or more were obese (mean BMI was at least 30 kg/m^2^). On average, HbA1c levels implied suboptimal control of blood glucose in the included patients (mean level was approximately 8% or greater in all trials). An elevated HbA1c level was a prerequisite (based on the inclusion criteria) in at least two trials (Guerci 2003 and Schwedes 2002).

#### Study results

(Figure 2, Panel B)

Figure 2 The effect of SMBG on HbA1c (%) in cohorts of patients using SMBG

Squares indicate baseline HbA1c for each cohort. Solid lines indicate the change in HbA1c from baseline (Panel A, final vs baseline) or net change [change in SMBG cohort minus change in No SMBG cohort] (Panel B). Dotted lines are 95% confidence intervals of changes or net changes in HbA1c (generally not reported, therefore estimated from available data). Light gray diagonal line is line of identity. Studies/cohorts are distributed along y-axis only to allow visualization of distribution of baseline values. Only final followup timepoint data from each study are included.

Open squares in Panel A are 3 cohorts all from the same study. Open circle in Panel B is a nonrandomized study.

Panel A. SMBG cohorts (baseline and final HbA1c (%)). Panel B. SMBG vs No SMBG (baseline in SMBG cohort and net change HbA1c (%))

The studies are inconclusive about whether use of SMBG resulted in clinically significant reductions in HbA1c in studies of patients with type 2 diabetes. The two largest trials (Guerci 2003 and Schwedes 2002) found that the net differences between SMBG and no SMBG were small (<0.5%), but highly statistically significant (both P = 0.009). Only one small study (Kibriya 1999) found a relatively large net difference in HbA1c (−1%), though it was unclear whether this effect was statistically significant. The remaining two trials found no clinically or statistically significant benefit on HbA1c of SMBG.

#### Conclusion

Overall, we identified five RCTs that met our inclusion criteria. These RCTs have fair applicability to people with type 2 diabetes in the Medicare population, although they typically enrolled younger patients and perhaps patients with a shorter duration of diabetes. The frequency of glucose monitoring was variable, as was the length of the intervention, the proportion of patients who needed insulin at baseline and the type of concomitant treatments. Importantly, only one of the studies reported that they advised patients to alter their diabetes treatment based on the SMBG readings. The studies may suggest a small, though possibly clinically nonsignificant, reduction in HbA1c with SMBG; though overall the studies are inconclusive. There was no clear pattern across studies regarding how the intensity of the SMBG protocols (frequency of monitoring) or baseline HbA1c related to net changes in HbA1c. The studies were each very different in how frequently (and on which days) SMBG was performed. In addition, given that most of the studies did not report how patients or clinicians changed their behavior or treatments, these analyses do not explain how the use of SMBG resulted in improved HbA1c. No eligible study evaluated continuous glucose monitoring or other home blood glucose measurement techniques.

### Cohort studies

(Table 8)

Table 8 Nonrandomized controlled and cohort studies of self monitoring of blood glucose levels and glycemic control

8.a Applicability of “large” prospective studies to non-dialysis-dependent Medicare population (baseline data)

Author, Year UI | N | Mean Age (Range) | ~%≥65 yr | Mean Duration DM | % DM 2 | % Using Insulin
Nonrandomized controlled study
Rutten, 1990 2289639 | 127 | 63 (40–75)^a^ | ~50% | 8.8 yr | 100% | nd
Cohort studies
Franciosi, 2005 15975106 | 1896 | 62 (nd) | <50% | 9.1 yr | 100% | 0%
Ozmen, 2003 12738396 | 267 | 58 (nd) | <50% | 8.6 yr | 100% | 34%
Miles, 1997 9270457 | 150 | 65 (31–91) | ~50 | 0 (newly diagnosed cases) | 100% | nd (probably 0% but not explicitly stated)
Halimi, 2001 11852377 | 143 | 40 (≥18)^a^ | <<50% | 14.2 yr | nd | 100%
Banister, 2004 15127069 | 70 | 49 (nd) | <<50% | nd | 100% | nd

a Eligibility criteria

8.b Baseline “severity of disease” in studies

Author, Year UI | Mean A_1c_ (Range) | % CVD (Details) | Mean GFR [SCr] (Range) | Mean Albuminuria (Category) | % Retinopathy (Details) | Other Comorbidities | Mean BMI (Range)
Nonrandomized controlled study
Rutten, 1990 2289639 | 9.3 (nd) | nd | nd | nd | nd | nd | QI: 51% <27, 21% 27–30; 27% >30
Cohort studies
Franciosi, 2005 15975106 | 7.2 (nd) | nd | nd | nd | nd | Mean total illness burden index = 12.7 | 28 (nd)
Ozmen, 2003 12738396 | 9.1 (4% <6, 17% 6.1–6.9, 20% 7.0–7.9, 16% 8–8.9; 44% >9) | nd | nd | nd | 28% background diabetic retinopathy (DR) 20% had proliferative DR | nd | 29.1 (nd)
Miles, 1997 9270457 | 10.3 (nd) | nd | nd | nd | nd | nd | 27.3 (nd)
Halimi, 2001 11852377 | Monitor A: 9.8 Monitor B: 9.5 Monitor C: 9.3 (nd) | nd | nd | nd | nd | nd | 24.1 (nd)
Banister, 2004 15127069 | 9.7 (5.2–16.2) | nd | nd | nd | nd | nd | 34 (90% >25)

QI, Quetelet index (<27 = acceptable, 27–30 = over weight, >30 = obesity)

8.c Study designs

Author, Year UI | Design | Intervention Year(s) | Study Duration | Intervention (Frequency) | Control | Other DM Treatments/Cointerventions
Nonrandomized controlled study
Rutten, 1990 2289639 | Prospective, nRCT | <1990 | 1 yr | SMBG when desired by the patient Medications adjusted based on SMBG readings, as necessary | No SMBG
Cohort studies
Franciosi, 2005 15975106 | Cohort | <2005 | 3 yr | Self-reported SMBG frequency (≥1/d, ≥1/wk, <1/wk or never) No active interventions | | Diet only, Sulfonylureas, Metformin, or Sulfonylureas + metformin
Ozmen, 2003 12738396 | Cohort | 1997–2001 | 1 yr | SMBG (Month 1: 2–3x/wk. During the next 11 mo: as necessary to maintain normoglycemia). Clinicians evaluated SMBG readings to adjust treatment | | Diet alone, insulin +/− Sulfonylureas, acarbose or metformin
Miles, 1997 9270457 | Cohort | 1993–1994 | 3 & 6 mo. | SMBG (1/d) Did not report training on how to respond to readings
Halimi, 2001 11852377 | Cohort | <2001 | 6 mo. | SMBG (4x/d, 3 different monitors) Did not report training on how to respond to readings | | All patients were insulin-treated.
Banister, 2004 15127069 | Cohort | 2001 | 2–12 mo | SMBG (1x/d) Did not report training on how to respond to readings

8.d Study Results

Author, Year UI | Outcome | N (Tx) | N (Cx) | Effect Magnitude (Change in Control Group) | | | | Significant?
Nonrandomized controlled study
Rutten, 1990 2289639 | Mean changes in HbA1c | 55 | 72 | Net Δ = −0.94% (Cx: +0.46%) b | | | | <0.01
Cohort studies
Franciosi, 2005 15975106 | HbA1c | 1896 | | No effect of SMBG practice on metabolic control | | | | NS
Ozmen, 2003 12738396 | HbA1c | 267 | | 6 mo Δ = −1.3% | | | | 0.001
Ozmen, 2003 12738396 | HbA1c | 267 | | 12 mo Δ = −1.9% | | | | 0.001 (6 mo vs 12 mo NS)
Ozmen, 2003 12738396 | HbA1c, stratified by optic fundi findings | 267 | | | Mean HbA1c
Ozmen, 2003 12738396 | HbA1c, stratified by optic fundi findings | 267 | | | Baseline | 6 mo | 12 mo
Ozmen, 2003 12738396 | HbA1c, stratified by optic fundi findings | 267 | | No DR | 7.9 | 6.7 | 5.8
Ozmen, 2003 12738396 | HbA1c, stratified by optic fundi findings | 267 | | Background DR | 9.6 | 7.8 | 8.3
Ozmen, 2003 12738396 | HbA1c, stratified by optic fundi findings | 267 | | Proliferative DR | 11.7 | 8.9 | 8.0
Miles, 1997 9270457 | HbA1c | 58 | | 3 mo Δ = −1.5% (−1.9, −1.06) | | | | <0.05
Miles, 1997 9270457 | HbA1c | 58 | | 6 mo Δ = −2.5% (−3.9, −1.3) | | | | <0.05
Halimi, 2001 11852377 | HbA1c | 143 | | 3 mo Δ = −0.3% (monitor A) −0.7% (monitor B) −0.64% (monitor C) | | | | <0.05 (NS between monitors)
Halimi, 2001 11852377 | HbA1c | 143 | | 6 mo Δ = −0.6% (monitor A) −0.9% (monitor B) −1.0% (monitor C) | | | | <0.05 (NS between monitors)
Banister, 2004 15127069 | HbA1c | 70 | | −1.5% | | | | <0.001

DR, diabetic retinopathy; Cx, change from baseline in control group

b Adjusted for baseline HbA1c

#### Study descriptions

We identified one nonrandomized controlled study66 and five single-arm, uncontrolled cohort studies meeting eligibility criteria.67–71 We included all prospective studies with a minimum sample size of 50 subjects and a minimum 3-month duration of follow-up. The sample size of these six studies ranged from 70 to 1,896 patients. The studies were heterogeneous in their settings.

The frequency of glucose monitoring in the five cohort studies ranged widely, from two to three times a week to four times daily. In the Rutten 1990 study, SMBG was performed when desired by the patients in the intervention arm but the frequency of SMBG was not reported; the patients in the control arm were not instructed in SMBG. Both Rutten 1990 and Ozmen 2003 reported that antidiabetes treatments were adjusted based on SMBG readings. How SMGB readings were acted on by the other studies was not reported. The intervention years were before 1990 in one study (Rutten 1990), 1993 to 1994 in another study (Miles 1997), and after 1997 for the other four studies.

#### Applicability to the Medicare population

The mean age of the study participants ranged from 40 to 65 years old at baseline. Only the nonrandomized controlled study, Rutten 1990 and the cohort study Miles 1997 had patient samples about half of whom were 65 years or older. No study performed separate analyses for older patients. All patients had type 2 diabetes, with the exception of patients in Halimi 2001, which did not report diabetes type, but probably included at least some patients with type 1 diabetes. The mean duration of diabetes ranged from newly diagnosed to 9 years. Only Halimi 2001 reported that all patients used insulin. A minority of patients used insulin in three studies; two studies did not report insulin use. Two studies reported that sulfonylureas and/or metformin were also used (Franciosi 2005 and Ozmen 2003). The mean baseline HbA1c levels ranged from 7% to 10%.

#### Study results

(Figure 2, Panel A)

Statistically significant improvements in glycemic control as measured by HbA1c were found in the nonrandomized comparative study (SMBG vs. no SMBG) and four of five of the uncontrolled cohort studies (final vs. baseline). The nonrandomized controlled study (Rutten 1990) and Halimi 2001 (which probably included many patients with type 1 diabetes) found improvements in HbA1c that were similar to the effects found in the randomized controlled trials. However, three of the cohort studies (Ozmen 2003, Miles 1997, and Banister 2004) found considerably larger changes from baseline, approximately −1.5% to −2.5%.

In contrast, in a 3 year prospective cohort study where patients continued using SMBG as they (and presumably their clinicians) saw fit, no effect of SMBG practice on metabolic control was found.

#### Conclusion

Overall, the nonrandomized study and the uncontrolled cohort studies were in general agreement with the findings of the randomized controlled trials, which indicate that use of SMBG is associated with a small reduction in HbA1c. Interpretation of these results, without equivalent control arms, though is difficult. This is particularly true since studies included patients with different stages of diabetes (though in general, none was insulin dependent) and required different interventions (i.e., diet alone, different drugs). Also similar to the randomized controlled trials, though, the majority of subjects were younger than 65 years old. Along with poor reporting regarding comorbidities and antidiabetic medication use, the age of the included subjects calls into question the applicability of these studies to the Medicare population.

## Self monitored blood glucose and risk of severe hypoglycemia in patients with type 2 diabetes

(Table 9)

Table 9 Studies of self monitoring of blood glucose levels and hypoglycemia

9.a Applicability of “large” prospective studies to non-dialysis-dependent Medicare population (baseline data)

Author, Year UI | N | Mean Age (Range) | ~%≥65 yr | Mean Duration DM | % DM 2 | % Using Insulin
Murata, 2004 15163479 | 344 | 65 (35, upper nd)^a^ | ~50% | 14.5 yr | 100% | 100%
Halimi, 2001 11852377 | 143 | 40 (≥18) | <<50% | 14.2 yr | nd | 100%
Cox, 1994 7989471 | 78 | 38 (nd) | <<50% | 19.3 yr | nd | 100%

a Based on inclusion criteria.

9.b Baseline “severity of disease” in studies

Author, Year UI | Mean A_1c_ (Range) | % CVD (Details) | Mean GFR [SCr] (Range) | Mean Albuminuria (Category ^A^) | % Retinopathy (Details) | Other Comorbidities | Mean BMI (Range)
Murata, 2004 15163479 | 8.0 (nd) | 35% PVD 5% LE amputation 14% LE ulcers 30% MI 13% stroke | <2.8 mg/dL | nd | 32% retinopathy (No details) | 70% described themselves as self-disabled 58% neuropathy | 32.0 (nd)
Halimi, 2001 11852377 | 9.6 | nd | nd | nd | nd | nd | 24.1
Cox, 1994 7989471 | 10.3 (nd) | nd | nd | nd | nd | nd | nd

PVD, peripheral vascular disease; MI, myocardial infarction; LE, lower extremity

9.c Study Designs

Author, Year UI | Design | Intervention Year(s) | Study Duration | Intervention (Frequency) | Control | Other DM Treatments/Cointerventions
Murata, 2004 15163479 | Cohort | 2001–2002 | Up to 52 wk | SMBG (15.3x/wk)^b^ Patients instructed in diabetes management based on SMBG readings | | Per patients’ primary care physicians
Halimi, 2001 11852377 | Cohort | <2001 | 6 mo | SMBG (4x/day) Did not report training on how to respond to readings | Insulin
Cox, 1994 7989471 | Cohort | <1994 | 6 mo | SMBG (≥2x/day) No training on how to respond to readings (implied) | Insulin

b It appears as if the 15.3x/wk only regards those patients who developed hypoglycemia throughout the study duration; however, this is not made clear. A subset (n = 159) intensified SMBG – 4× daily – for 8 weeks and then resumed their ‘usual’ frequency.

9.d Study Results

(all uncontrolled cohort studies)

Author, Year UI | Outcome (Definition) | N (Tx) | N (Cx) | Effect Magnitude | Significant?
Murata, 2004 15163479 | Symptomatic hypoglycemia (See footnote c) | 344 | | 52% of total had at least one symptomatic hypoglycemic episode
Murata, 2004 15163479 | Symptomatic hypoglycemia (See footnote c) | 344 | | The average symptom score was 0.85 d
Halimi, 2001 11852377 | Weekly hypoglycemic episodes (not defined) | 143 | | Increased from an average of 1.9 episodes to an average of 6.2 episodes
Halimi, 2001 11852377 | Hospitalizations/severe adverse events (not defined) | 143 | | No patients were hospitalized or suffered any severe adverse events
Cox, 1994 7989471 | Severe hypoglycemia (unconsciousness or stupor, assistance is required) | 78 | | Mean 8.6 episodes of hypoglycemic stupor and 0.81 episodes of hypoglycemic unconsciousness during the 6 mo period
Cox, 1994 7989471 | Severe hypoglycemia (unconsciousness or stupor, assistance is required) | 78 | | 20 (26%) subjects reported no severe hypoglycemic episodes during the 6 mo

c Hypoglycemia was defined as a recorded glucose level ≤60 mg/dL. An episode was considered symptomatic if the subject had relevant autonomic symptoms (palpitations, sweating, tremor) or neuroglycopenic symptoms (dizziness, loss of coordination, trouble concentrating).

d Symptoms were scored as ‘0’ if there were no symptoms, as ‘1’ if patient had mild-to-moderate symptoms and as ‘2’ if patient had a depressed level of consciousness or required the assistance of others. For each subject, a representative symptom score (on a scale of 0–2, based on the scoring of symptoms) was calculated for each hypoglycemic episode.

### Study descriptions

We identified three cohort studies meeting our inclusion criteria (Murata 2004, Halimi 2001, and Cox 1994).69,72,73 We included all prospective studies with a minimum sample size of 50 subjects and a minimum duration of follow-up of 6 months. No comparative studies (randomized or nonrandomized) reported on severe hypoglycemia outcomes. The sample sizes of these studies were 344, 143, and 78 patients, respectively. Halimi 2001 and Cox 1994 are similar with respect to their interventions and study duration. In these two studies, the frequency of glucose monitoring ranged from two to four measurements daily and the duration of the intervention was 6 months. In Murata 2004, it is indicated that patients monitored their blood glucose at an average of 15.3 measurements per week and that the duration of the intervention was 1 year. It appears as if the number of measurements only regards those patients who developed hypoglycemia throughout the study duration; however, this is not made clear. In addition, it was reported that 159 of the 344 patients intensified their monitoring to four measurements daily for 8 weeks and then resumed the original intervention. Patients in all studies were insulin-treated. In addition, diabetes treatments were determined by the patients and their primary care physicians in Murata 2004; however, the particular treatments are not mentioned. Patients in the Cox 1994 study underwent Blood Glucose Awareness Training in order to learn greater awareness of blood glucose fluctuations.

### Applicability to the Medicare population

All patients in Murata 2004 had insulin-treated type 2 diabetes; however, it is not specified how many patients had type 2 diabetes in Halimi 2001 and Cox 1994. It is possible that a sizeable number of subjects in these two studies had type 1 diabetes as the mean ages and the mean durations of diabetes diagnosis data imply that many patients were diagnosed in their 20s. The mean age of the participants ranged from 38 to 65 years. In all the studies, no more than 50 percent of the patients were older than 65 years; in Cox 1994, none of the patients was older than 65 years. No study performed separate analyses for older patients. The mean duration of diabetes in patients was about 14 to 15 years in two of the studies (Murata 2004 and Halimi 2001) and 19 years in the other study (Cox 1994).

Halimi 2001 and Cox 1994 did not report any information regarding the presence of cardiovascular disease, kidney disease, retinopathy and other comorbidities in their patients. Some patients in the Murata study presented with vascular disease, stroke, micro- and macrovascular complications, myocardial infarction, retinopathy, “self-disability”, neuropathy and lower extremity amputations and/or ulcers. Mean HbA1c in all studies was greater than 8%, indicating suboptimal control of blood glucose. Patients in Murata 2004 and Halimi 2001 had a mean BMI of 32.0 and 24.1 kg/m^2^, respectively. Information on the mean BMI of patients in the Cox study was not provided.

### Study results

The largest study, Murata 2004, measured symptomatic hypoglycemic episodes, defined as hypoglycemia with autonomic symptoms: palpitations, sweating, tremor, or neuroglycopenic symptoms: dizziness, loss of coordination and trouble concentrating. It is unclear how many of the episodes were of grade 3 or 4 severity. During 1 year of SMBG, 52 percent of patients had at least one episode of symptomatic hypoglycemia. Symptoms were scored as ‘0’ if a patient did not experience any symptoms, as ‘1’ if a patient had mild-to-moderate symptoms and as ‘2’ if a patient had a depressed level of consciousness or required the assistance of others. For each subject, a representative symptom score, on a scale of 0–2, was calculated for each hypoglycemic episode. The mean symptom score was 0.85.

Halimi 2001 reported that the number of weekly hypoglycemic episodes during the 6 months increased from an average of 1.9 episodes to an average of 6.2 episodes. Halimi 2001 also reported no hospitalizations or severe adverse events. Statistical significance was not provided for any of these results.

In the Cox 1994 study, subjects reported a mean of 8.6 episodes of hypoglycemic stupor and 0.81 episodes of hypoglycemic unconsciousness over 6 months of SMBG; 25 percent of subjects reported no severe hypoglycemia episodes.

### Conclusions

Though three cohort studies met the inclusion criteria for this report, there are no data regarding the rate of severe episodes of hypoglycemia among patients all of whom have type 2 diabetes. Only one study (Murata 2004) definitely included only patients with type 2 diabetes; approximately half of the subjects were age 65 years or older. The other two studies were of much younger populations and may include a large number of patients with type 1 diabetes. In two of the studies (Cox 1994 and Murata 2004), over half of the patients suffered from severe hypoglycemia and in the third study (Halimi 2001), the number of weekly hypoglycemic episodes increased by an average of four episodes. Hypoglycemia occurred among a sizeable number of patients performing self-monitoring of blood glucose levels; however, as these patients were not compared to patients who were not self-monitoring, it is difficult to determine to what degree SMBG played a role in the hypoglycemia events, as opposed to other changes that occurred in the patients’ diabetes management during the course of the studies.

## Correlation of self-monitoring frequency with outcomes in patients with type 2 diabetes

(Table 10)

Table 10 Correlation of SMBG frequency and achieved HbA1c

Author, Year UI | N | | Study Duration | Predictor | Statistical Method | Outcome | Effect | P-value
Author, Year UI | Tx | Cx | Study Duration | Predictor | Statistical Method | Outcome | Effect | P-value
HbA1c outcome
Franciosi, 2005 15975106 | 1896 | -- | 3 yr | Increase in monitoring frequency a | Regression | ΔHbA1c | β= −0.13 | 0.08
Franciosi, 2005 15975106 | 1896 | -- | 3 yr | Among patients who changed frequency without changing treatment a | Regression | ΔHbA1c | β= −0.015 | 0.6
Fontbonne, 1989 2630378 (See study Figure 3) | 56 | (54)^b^ | 6 mo | No. BG strips used c | Regression | ΔHbA1c | ▲Strips → ▼A1c r=0.36 | <0.02
Fontbonne, 1989 2630378 (See study Figure 3) | 56 | (54)^b^ | 6 mo | No. BG strips used c | t test | ΔHbA1c | ΔHbA1c≥1% (229 strips) vs. <1% (153 strips) | <0.01

BG strips, blood glucose reactive strips

a Observational study. No protocol was reported regarding what changes were made based on SMBG readings.

2 Not included in analysis.

c Study did not report on any training on how to respond to SMBG readings.

### Study descriptions

Two of the studies on SMBG reported analyses correlating SMBG frequency with achieved HbA1c; no study attempted to correlate SMBG frequency with hypoglycemia episodes or clinical events.62,68 Fontbonne 1989 was a 6 month randomized controlled trial comparing SMBG to usual care in patients with type 2 diabetes who were not using insulin treatment. The study did not report how patients’ management of their diabetes was altered based on the SMBG readings. Franciosi 2005 was a large prospective, observational uncontrolled, 3 year cohort study, also of patients with type 2 diabetes who were not using insulin treatment. As an observational study, there was no protocol regarding how patients or clinicians responded to SMBG readings. Overall, these studies had fair applicability to the Medicare population (details have been given in the previous sections).

### Study results

Franciosi 2005 evaluated 1896 patients with type 2 diabetes using SMBG for 3 years. The patients were not following a specific SMBG protocol. The study reported that “changes in SMBG frequency during the study period failed to show any statistically significant impact on metabolic control.” Overall, there was a trend that increasing the frequency of SMBG was associated with a slight decrease in mean HbA1c (β = −0.13; P = 0.08). However, among patients who changed frequency of monitoring, but did not change treatment of their diabetes, there was no correlation between frequency and HbA1c. The study did not report what units were used for frequency of SMBG, making the betas uninterpretable.

Among the subjects randomized to the SMBG arm, Fontbonne 1989 correlated the number of blood glucose strips used with the change in HbA1c over a 6 month period. Linear regression yielded a statistically significant correlation (P<0.02) such that, by regression, using no strips predicts an increase in HbA1c of approximately 1%, while using 500 strips in 6 months predicts a decrease in HbA1c of approximately 3% (See Figure 3 in study article). However, three issues raise concern regarding the validity of this finding: 1) the likelihood that a single extreme point (at over 500 strips) is a leverage point, unduly affecting the analysis; 2) the question of whether test strips used is a valid proxy for SMBG frequency (or of difficulty performing the tests without wastage); and 3) the protocol implies that about 200 strips should have been used during the 6 months, but many patients used many more than 200 strips. In a separate analysis, those patients who obtained a decrease in HbA1c of ≥1% used significantly more strips than those with smaller changes (229 vs. 153 strips, P<0.01).

### Conclusions

Given the problems with the two studies and the weak findings, no firm conclusion can be drawn regarding the correlation between frequency of SMBG and achieved HbA1c. Furthermore, any such correlation would clearly be a proxy for the effect of modifications in diet, diabetes treatment, or other factors on glycemic control. The correlation between number of strips used and change in HbA1c may be a proxy for how intensely patients are interested in their glycemia. Possibly, those patients who chose to monitor frequently were more likely to alter their diet, have more intensive treatment, and be more adherent to the diabetes management plan.

Since the reference studies for this report were completed, several oral and injectable hypoglycemic medications as well as new types of insulin (e.g., long-acting, analogs, pre-mixed analogs and inhaled insulin) have become available for the treatment of type 2 diabetes. Some of these medications are rapidly replacing old medications (e.g., insulin analogs are replacing human insulin) while others have been embraced by clinicians and are extensively used in clinical practice. The new hypoglycemic medications and insulin do not necessitate increased use of SMBG; however, the findings of this report may have limited application in patients treated with the new medications. Its findings will need to be updated to incorporate any new studies on SMBG and outcomes which include use of the new hypoglycemic agents.