# Methods

## Key questions addressed in this report

The key questions in this report sought to identify the existing scientific evidence regarding the frequency of glucose testing and glycemic control and its applicability to the majority of Medicare diabetes patients (patients with type 2 diabetes who are age 65 years and older). Specifically:

1. Provide background information on type 1 and type 2 diabetes and their complications, and information on the prevalence of the types of diabetes in the Medicare population. Briefly compare and contrast types 1 and 2 diabetes and their complications. Provide a brief narrative review of the evidence on glucose monitoring in type 1 diabetes patients.
2. Through the systematic review process, describe the applicability of the literature to the non-dialysis-dependent Medicare population in regards to the following three (3) questions:
  A. The relationship between tighter glycemic control and clinical outcomes (both benefits and harms) in patients with type 2 diabetes.
  B. The effect of frequency of glucose monitoring on clinical outcomes in patients with type 2 diabetes.
  C. The effect of frequency of glucose monitoring on glycemic control (HbA1c) in patients with type 2 diabetes.

Furthermore it was requested that:

For questions 2.A–C, there should be a specific focus on generalizability of studies to Medicare patients, outcomes measured, study design and time scale of studies. Inclusion criteria for studies in questions 2.A–C: prospective, including observational; comparative only; minimum duration 1 year for clinical outcomes (macrovascular [cardiovascular], microvascular [retinopathy, nephropathy], and neuropathy using hard clinical outcomes such as myocardial infarction, stroke, amputation, dialysis, legal blindness, 3 step change in retinopathy score), 3 months for hypoglycemia outcomes (hyperosmolar coma, and blood/serum glucose < 50 mg/dL and requiring third party intervention or blood/serum glucose < 30 mg/dL), and 3 months for glycemic control outcomes (HbA1c, glycated hemoglobin);.

## Literature search strategy

We conducted a comprehensive literature search for publications on frequency of monitoring and glycemic control in MEDLINE. An iterative process was used where the search strategy was successively revised based on articles that were found to be missing from the original search, and based on changes to the key questions during the development process. The final search was performed April 18, 2006. The search included English language articles on diabetes (types 1 and 2) in adults with relevant study designs. These studies were crossed with articles on blood glucose self monitoring; drug administration schedules; insulin infusion systems; insulin; blood glucose analysis; physiologic monitoring; patient education; and glucose monitoring, testing, screening, control, and related terms. Systematic reviews and guidelines pertinent to the key questions that were found from this search were retrieved. The reference lists of these articles were used to find additional articles. As noted above, the missing articles were also used to revise the original literature search.

## Study selection

Two people screened all abstracts identified through the literature search. At this stage all studies, regardless of study design or sample size, that evaluated any form of glycemic control or of self-monitoring were tentatively accepted. Upon finalization of the key questions, these abstracts were rescreened to select those articles for retrieval.

The eligibility criteria for this report were strict, requiring relatively large numbers of subjects and long-term follow-up. The decision to limit the scope of the systematic review was based on the needs of the MedCAC panel and the available timeframe and resources available for the review. Thus, this report reviews only the studies that are likely to provide the “strongest” evidence. Compared with large studies, smaller studies with short follow-up typically have fewer events and are therefore less likely to be adequately powered for outcomes of interest. Retrospective analyses were not included since these can be hypothesis generating only.

The following eligibility criteria were used.

### Population

Adults (age ≥ 18 years) with type 2 diabetes of any duration, who were not hospitalized (outpatient population), regardless of therapies received were included. We excluded studies of patients who predominantly had end-stage renal disease or who were pregnant. Studies where more than half the subjects had type 1 diabetes were excluded.

### Interventions

Acceptable interventions included intensive glycemic control where the goal of treatment was to reduce HbA1c or other measures of glycemic control to near normal, regardless of method used and self-monitoring of blood glucose, regardless of method, including continuous glucose monitoring.

### Comparators

None required, but comparators of interest were usual care glycemic control, glycemic control with a goal above normal, or no self-monitoring of blood glucose; self-monitoring of urine glucose was ignored.

### Outcomes

Articles with the following outcomes were included, if otherwise eligible. When outcomes were deemed to be sufficiently similar to the outcomes of interest, we favored inclusion of the outcomes. Abstracts were not relied on to determine study eligibility based on reported outcomes.

Clinical outcomes. Mortality, all-cause, or event-related; cardiac events (e.g., myocardial infarction, heart failure); cerebrovascular events; peripheral vascular events (e.g., intermittent claudication); peripheral neuropathy events (i.e., lower extremity ulceration or amputation); kidney events (e.g., dialysis); and retinopathy events (e.g., blindness, 3-step change in retinopathy score).

Hypoglycemia outcomes. Severe hypoglycemia events such as Stage 3 or 4 hypoglycemia, where patients require assistance from someone else. However, we allowed various definitions of severe hypoglycemia. When the definitions provided by the studies were unclear, we favored including the studies. We also reviewed studies for reporting of other adverse events related to the interventions.

Glycemia outcomes. For studies of SMBG, we included studies with any measure of glycohemoglobin, favoring HbA1c over other measures of glycohemoglobin when evaluating effects. We did not include fasting blood glucose or other measures of glycemia as outcomes. We also did not review success at achieving lower HbA1c with intensive glycemic control.

### Study design

We included only prospective studies of any design, including randomized controlled trials; nonrandomized, prospective comparative studies (intervention vs. control, but not randomized); and prospective cohort studies (i.e., pre-post studies without a control group).

Clinical outcomes. For clinical outcomes, we included only those studies that evaluated at least 100 subjects in the intervention arm. The minimum duration of follow-up was 12 months.

Adverse events or glycemia outcomes. For nonclinical outcomes, we included only those studies that evaluated at least 50 subjects in the intervention arm. The minimum duration of follow-up was 3 months.

## Data extraction

“Evidence Tables” were created to capture all the data of interest for this report. Data were extracted directly into these tables. A single reviewer extracted each eligible study. All data entries were reviewed by at least one other reviewer. Any data extraction issues were reviewed at weekly meetings and resolved through consensus. Occasional sections were re-extracted to ensure that uniform definitions were applied across all extracted studies. Any problems or corrections were noted through spot checks of extracted data and during the creation of summary and evidence tables. Items extracted included: factors related to study design (including type of study, intervention year, and study duration), population characteristics (including sample size, age, HbA1c, body mass index, percent using insulin, and comorbidities), interventions and control groups (glycemic control, frequency of glucose monitoring), outcomes of interest (number of patients in the treatment and control groups, clinical outcomes, hypoglycemia, HbA1c, and results, including within treatment change and/or between treatment differences).

A single reviewer also extracted reported analyses of “linearity” in all articles. That is, intensive glycemic control studies that analyzed whether achieved HbA1c was correlated to any of the outcomes of interest, or SMBG studies that analyzed whether frequency of self-monitoring was correlated to any of the outcomes of interest (including HbA1c).

As agreed upon with AHRQ and CMS Staff, study quality was not assessed for this report.