# Introduction

This technology assessment report on intensive glycemic control and self-monitoring of blood glucose (SMBG) in patients with type 2 diabetes mellitus is prepared by the Tufts-New England Medical Center Evidence-based Practice Center (Tufts-NEMC EPC) for a Medicare Evidence Development and Coverage Advisory Committee (MedCAC) meeting. The primary goal of the report is to describe the applicability of the larger, long-duration studies to the nondialysis Medicare population (i.e., people at least 65 years old).

The specific questions addressed are described in the Methods chapter (Chapter 2). The Center for Medicare and Medicaid Services (CMS) also requested a brief narrative review of diabetes (both type 1 and type 2), its epidemiology in the US, complications due to the disease and its treatment, intensive glycemic control, and patient monitoring of glycemia.

## Definition of diabetes

Diabetes mellitus is a group of metabolic disorders characterized by abnormal fuel metabolism, which results most notably in hyperglycemia and dyslipidemia, due to defects in insulin secretion, insulin action, or both. Diabetes is a serious chronic disease without a definitive cure, which is associated with significant morbidity and mortality, both acute and chronic.

### Types of diabetes

Type 2 diabetes, previously called non-insulin-dependent diabetes mellitus (NIDDM) is the most prevalent type, accounting for up to 95 percent of all cases of diagnosed diabetes.1 Approximately 5 percent of cases are due to type 1 diabetes, previously called insulin-dependent diabetes mellitus (IDDM).

Type 1 diabetes refers to cell-mediated autoimmune destruction of pancreatic beta islet cells, which leads to absolute insulin deficiency. All patients with type 1 diabetes require insulin for survival. Peak incidence occurs during puberty although disease onset can occur at any age. The incidence of type 1 diabetes is rising in almost all populations and the age at onset is declining. There are an estimated 500,000 to one million people with type 1 diabetes in the United States or 0.16 – 0.32 percent of the population; there are approximately 20,000 new cases per year. There is no known way to prevent type 1 diabetes.

Type 2 diabetes is characterized by varying degrees of insulin resistance and insulin deficiency. Resistance to the action of insulin results in impaired insulin mediated glucose uptake in the periphery (by muscle and fat) and incomplete suppression of hepatic glucose output. To overcome the insulin resistance (and therefore prevent abnormal fuel metabolism and maintain normal glucose and lipid levels), beta cells will increase the amount of insulin secreted. Higher circulating insulin levels will overcome the impedance to the action of insulin. This state of high insulin levels with euglycemia persists for many years. As the need for insulin (http://www.cdc.gov/diabetes/pubs/definitions.htm#Insulin) rises, the pancreas gradually loses its ability to produce it. The abnormal fuel metabolism characteristic of diabetes (hyperglycemia and dyslipidemia) occurs when there is a mismatch between insulin requirements, as dictated by insulin resistance, and insulin supply, as determined by beta cell function. The nature of the disease and its polygenic causes result in a wide range of insulin sensitivity and insulin secretion, thus in a wide range of clinical manifestations. Type 2 diabetes is associated with older age, obesity, family history of diabetes, history of gestational diabetes, impaired glucose metabolism, physical inactivity, and race/ethnicity (non-White). Type 2 diabetes will continue to be a major health problem in the United States and the developed world, as sedentary lifestyle and obesity, become more prevalent.

### Diabetes in the Medicare population

In general, type 1 diabetes is more prevalent in children and adolescents and the majority of type 2 diabetes cases occur in adults; however, the exact distribution of these two major types of diabetes by age is difficult to ascertain for a variety of reasons: (1) a great degree of clinical overlap exists between type 1 and type 2 diabetes, therefore, one cannot exclude either type of diabetes on the basis of the patient’s age alone. For example, a patient with type 2 diabetes but with severe insulin deficiency will require insulin and may be misclassified as type 1 diabetes; (2) specific testing is often required to identify the type of diabetes. Such testing is done infrequently in clinical practice; (3) once a patient is treated exclusively with insulin, clinicians frequently fail to identify the specific etiology of diabetes and refer to all insulin-requiring patients (whether they have type 1 or type 2) as IDDM; and (4) patients with type 1 diabetes are now expected to survive long enough to reach the Medicare age (65 years) and to suffer from other conditions associated with type 2 diabetes (hypertension, dyslipidemia etc) further complicating the clinical distinction between the types of diabetes.

## Epidemiology of diabetes

### General population

Diabetes is one of the most common chronic diseases in the US. It is estimated that in 1999–2002, 19.3 million US adults or about 9.3 percent of the total adult US population had diabetes (6.5 percent diagnosed and 2.8 percent undiagnosed).2 In 2005, approximately 1.5 million new cases of diabetes were diagnosed in US adults.1 At this rate, it is estimated that more than 25 million people in the US alone will have been diagnosed with diabetes by the year 2025.

The increase in the incidence and prevalence of diabetes over the last few decades and the rise anticipated over the next few decades can be attributed to many factors including, change in diagnostic criteria, increase in diagnosis due to increased awareness, aging of the population, decreasing mortality, increase in the prevalence of obesity and growth in minority populations.

### Medicare-specific

From 1980 through 2004, the prevalence of diagnosed diabetes increased in all age groups.1,2 However, diabetes, similar to other chronic conditions, disproportionately affects the older population. In general, throughout the time period 1980–2004, people aged ≥65 years had the highest prevalence among any age group. Furthermore, the prevalence of diabetes (diagnosed and undiagnosed) in people aged ≥65 years increased from 18.6 percent to 21.8 percent between 1988–1994 and 1999–2002, paralleling the increase in the total US adult population.1,2 It is estimated that currently over 22 percent of the population over 65 years old (eligible for Medicare) or 7.9 million individuals in the US have diabetes (15.8 percent diagnosed and 5.8 percent undiagnosed, Table 1).2 People aged ≥65 years make up almost 40 percent of all those with diagnosed diabetes, and the prevalence in this age group is more than 10 times that in people younger than 45 years of age.1 There were 575,000 new cases of diabetes among people aged ≥60 years in 2005.^1^

Table 1 Crude prevalence (percent population) of diabetes in men and women 65 years of age or older in the US in 1999–2002 (adapted from Cowie et al.2)

| Diagnosed Diabetes | Undiagnosed Diabetes | Impaired Fasting Glucose
Total Population | 15.8 (14.0–17.8) | 5.8 (4.1–8.0) | 39.1 (35.5–42.9)
Men | 15.8 (13.1–18.8) | 7.9 (5.5–11.2) | 43.2 (37.2–49.4)
Women | 15.9 (13.8–18.2) | 4.2 (2.5–6.9) | 36.0 (32.0–40.2)
Non-Hispanic Whites | 14.3 (12.3–16.5) | 6.0 (4.1–8.6) | 40.0 (36.2–43.9)
Men | 14.3 (11.5–17.7) | 8.3 (5.6–12.0) | 45.0 (38.5–51.7)
Women | 14.3 (12.0–16.9) | 4.2 (2.3–7.7) | 36.2 (31.8–40.9)
Non-Hispanic Blacks | 28.5 (22.8–34.9) | 7.2 (3.6–13.9) | 24.5 (17.9–32.5)
Men | 29.2 (21.5–38.2) | 7.6 (2.6–20.3) | 23.0 (13.6–36.2)
Women | 28.0 (21.6–35.5) | 6.9 (2.8–16.3) | 25.6 (18.8–33.8)
Mexican-Americans | 24.9 (22.0–28.0) | 7.8 (3.8–15.2) | 34.3 (27.8–41.6)
Men | 25.6 (20.3–31.8) | 8.0 (3.4–17.9) | 31.9 (24.4–40.6)
Women | 24.3 (19.0–30.6) | 7.6 (2.5–20.4) | 36.1 (25.3–48.5)

Data are % (95% CI). Data are based on NHANES standardized to the 2000 US Census population by age and sex for the total population and race/ethnic groups and by age for sex-groups.

Recently published lifetime risk and estimates of length and quality of life with diabetes are shown in Table 2 adapted from Narayan et al.3 As an example, the lifetime risk for diagnosis of diabetes in a cohort of individuals who reached the Medicare age (65 years) in 2005 was estimated at 19 percent for men and 22 percent for women.

Table 2 Residual lifetime risk for diabetes(adapted from Narayan et al.3)

Baseline Age (years) | Lifetime risk (%)
Baseline Age (years) | Men | Women
Birth | 33 | 39
10 | 32 | 38
20 | 32 | 37
30 | 31 | 36
40 | 30 | 33
50 | 26 | 28
60 | 19 | 22
70 | 11 | 15
80 | 5 | 7

Values obtained through a probabilistic sensitivity analysis.

Life expectancy of people with diabetes is estimated to be 4–19 years less than that for people without diabetes.3,4 Life shortening due to diabetes is negatively correlated with the age at diagnosis. In the older population with lower life expectancy because of other illnesses, diabetes contributes less to a shortened life expectancy. For example, a man diagnosed with diabetes at age 60 is estimated to live with diabetes for another 15 years, which represents a 7-year shortened life expectancy (11 years in quality-adjusted life years) compared to a 60-year old without diabetes.3 The primary cause of premature death is macrovascular disease, including heart disease and stroke.1 Also among those patients who develop kidney failure (microvascular disease), the primary cause of death is cardiovascular disease.5

There is also evidence to suggest that the overall health of older people with diabetes may worsen in coming years. As progressively younger people develop type 2 diabetes, the average duration of carrying the diagnosis will increase in older people. Furthermore, compared to people who develop diabetes later in life, those with early onset diabetes have been found to have substantially greater risks of insulin-dependence, microvascular and macrovascular disease, and specifically myocardial infarction.6

### Economic burden

The direct medical and indirect expenditures attributable to diabetes in 2002 were estimated at $132 billion.7 Of that amount, $92 billion was direct medical costs, 52 percent of which were incurred by people >65 years old. Approximately 57 percent of direct medical costs were due to inpatient care (hospitalization or nursing home).

## Complications of diabetes

### Acute complications

#### Hyperglycemia

Acute complications directly due to diabetes are related to severe hyperglycemia and include polyuria, polydipsia, polyphagia, weight loss and blurred vision. Patients may exhibit impaired growth and increased susceptibility to infections. Acute marked hyperglycemia may lead to diabetic ketoacidosis (DKA) in type 1 diabetes or to the hyperglycemic hyperosmolar nonketotic syndrome (HHNS) in type 2 diabetes.

#### Hypoglycemia

Patients with diabetes who are treated with oral medications (especially insulin-secretagogues) or insulin are also at risk for hypoglycemia. The latter is recognized as a major limitation in achieving good glycemic control. The frequency, severity and sequelae of hypoglycemia varies. Mild hypoglycemia is generally defined by the ability to self-treat while severe is defined by the need for external help (Grade 3 hypoglycemia requires oral carbohydrates with help of others; Grade 4 is hypoglycemic coma). With aging, symptoms of hypoglycemia become less intense because of an attenuation of the autonomic response to low blood sugar.8 The diminished symptomatic response limits the time available to treat and places the elderly at high risk for developing the neuroglycopenic symptoms of hypoglycemia. Furthermore, hypoglycemia in the elderly may result in falls and consequent serious morbidity, such as osteoporotic fractures or intracranial bleeding. The occurrence and severity of hypoglycemia can also be affected by interactions between antidiabetes medications and other medications and (diabetes-related) autonomic neuropathy. Target levels of glycemic control can also impact on hypoglycemia, such that it is likely that patients attempting to achieve lower target levels are more likely to overshoot into hypoglycemia.

In type 1 diabetes, mild hypoglycemia occurs approximately twice a week while the frequency of severe hypoglycemia ranges from 0.2 to 1.7 episodes per patient per year.8,9 The annual prevalence (number of patients reporting at least one episode) of severe hypoglycemia is 30–40 percent. Estimates on the frequency of hypoglycemia in patients with type 2 diabetes are less accurate for a variety of reasons. In the largest trial in type 2 diabetes patients aged 25–65 years (UKPDS), the reported mean proportion of patients with at least one episode of severe hypoglycemia was 0.6 and 2.3 percent for those on sulfonylurea and insulin respectively.10 In other smaller studies (age range 40–87 years), the prevalence of severe hypoglycemia was 0.6–0.8 percent on sulfonylurea and 0–15 percent on insulin. The frequency of severe hypoglycemia in type 2 diabetes patients (age range 27–87 years) is 0.02 to 0.35 episodes per patient per year, 10-fold lower than in type 1 diabetes. Age is a risk factor for severe hypoglycemia but specific data on the population over 65 are not available. Additional data on the risk of severe hypoglycemia with type 2 diabetes are presented below.

### Chronic complications

Chronic hyperglycemia leads to increased formation and accumulation of advanced glycation end products that contribute to the development of microvascular and macrovascular complications in diabetes. These complications in turn lead to end-organ damages, especially the eyes, kidneys, nerves, heart, and brain. Unfortunately, many patients with diabetes remain asymptomatic and undiagnosed for long periods, so that the first presentation of the disease is frequently a chronic complication. Indeed, about 50 percent of patients with newly diagnosed type 2 diabetes have already developed a vascular complication. Classically, chronic complications associated with diabetes are classified as microvascular or macrovascular. Frequently, however, microvascular and macrovascular complications coexist in the same individual. Furthermore, certain outcomes (e.g. heart disease) may be due to overlapping contributions of microvascular and macrovascular disease.

Microvascular complications include retinopathy with potential loss of vision, nephropathy leading to kidney failure, peripheral neuropathy contributing to pain, foot ulcers, and limb amputation and autonomic neuropathy causing gastrointestinal, genitourinary, cardiovascular symptoms and sexual dysfunction. In patients with diabetes, the association of autonomic neuropathy with cardiovascular disease provides a good example of microvascular disease interacting with macrovascular disease to exacerbate morbidity. For example, neuropathy may mask the pain of myocardial disease and may cause orthostatic hypotension. Microvascular complications are a significant cause of morbidity. Diabetes is the leading cause of blindness (12,000 – 14,000 new cases/year), chronic kidney disease (44,400 new cases of end-stage kidney disease) and nontraumatic limb amputation (82,000 per year) in the US. Persistent chronic hyperglycemia is the major contributor to the microvascular complications, which are highly specific for diabetes. The microvascular complications occur more commonly in patients with type 1 diabetes.11 In the UKPDS trial of people 65 years and younger with newly diagnosed type 2 diabetes, over about a decade approximately 11 microvascular events (retinopathy and kidney failure) occurred per 1000 patient-years (in the conventional treatment arm).12

Macrovascular complications include coronary heart disease, peripheral vascular disease and cerebrovascular disease (stroke). Compared to people without diabetes, persons with diabetes are 2 to 4 times more likely to develop heart disease or suffer a stroke. People with diabetes, but without previous myocardial infarction, have as high a risk of myocardial infarction as people without diabetes who have had a previous myocardial infarction.13 Macrovascular complications are the main cause of mortality, specifically heart disease and stroke account for about 65 percent of deaths in people with diabetes.1 Although persistent chronic hyperglycemia is recognized to contribute to macrovascular complications, associated conditions (hypertension, dyslipidemia, smoking) appear to be the primary contributing factors to the macrovascular complications. Therefore, macrovascular complications are more common in patients with type 2 diabetes who frequently exhibit a dysmetabolic syndrome.12,14 The UKPDS trial found that approximately 24 macrovascular events (myocardial infarction, stroke, or peripheral vascular events) occurred per 1000 patient-year in the conventional treatment arm.12

There are no long-term studies in the “average” US population, similar to the UKPDS study that report the incidence of vascular complications in patients with type 2 diabetes. An ongoing large study (LOOK AHEAD, www.niddk.nih.gov/patient/SHOW/lookahead.htm) sponsored by the National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK) will provide such data. In large studies conducted by pharmaceutical companies or meta-analyses of smaller studies, the incidence of macrovascular complications in patients with type 2 diabetes varied from under 10 to over 60 events per 1000 patient-years depending on whether included patients were at low or high risk for cardiovascular outcomes, respectively.15–19 However, these studies included patients from outside the US. In observational studies, the cardiovascular disease incidence in patients with diabetes varied from 15 to 60 per 1000 person-years.20,21

#### Mortality

In 2002, diabetes was the sixth leading cause of death based on the 73,249 US death certificates in which diabetes was listed as the underlying cause of death. According to death certificate reports, diabetes contributed to a total of 224,092 deaths, though diabetes is likely to be underreported as a cause of death. Overall, the risk for death among people with diabetes is about twice that of people without diabetes of similar age. All-cause mortality occurred approximately 19 times per 1000 patient years in the conventional treatment arm of UKPDS.12

## Technologies for monitoring blood glucose

Monitoring glycemic status is of paramount importance in the management of diabetes, because it provides the means to evaluate efficacy of treatment and guide further therapeutic interventions. Glucose monitoring has been traditionally achieved by a combination of testing during office visits and self-monitoring of blood glucose by patients on a daily basis.

### Hemoglobin A1c (HbA1c)

Hyperglycemia causes glycosylation of hemoglobin to an extent dependent on the ambient glucose level. Glycosylated hemoglobin (its major form being HbA1c) provides an excellent measure of the degree of glycemia over the proceeding 2–3 months, and its levels are correlated with microvascular and macrovascular complications in observational and interventional studies. As a result, HbA1c is commonly used in clinical practice as the primary test for monitoring glycemic status and guiding therapy.

### Self-monitoring of blood glucose (SMBG)

HbA1c provides a quantitative and reliable way of monitoring long-term glycemic control and guiding therapy; however, it is of little value in helping patients manage their glycemia on a daily basis. SMBG allows patients to monitor their glycemic status and make adjustments to their regimen on a day-to-day basis. Specifically, SMBG can allow patients to more finely adjust their insulin and other antidiabetes medication doses, diets, and exercise levels and patterns. SMBG may also allow patients to identify problem foods or activities that cause spikes in their blood glucoses. Thus, SMBG can result in positive feedback of better management techniques for patients. As such, SMBG, when used, should be incorporated into an overarching diabetes management plan, not used as a stand alone intervention. Until recently, the only clinically available method for SMBG was the use of capillary blood glucose monitors but newer glucose monitoring technologies are emerging, as described below.

It should be noted that home monitoring is a multibillion-dollar industry with sales forecast to reach $3 billion in 2008.

#### Capillary Blood Glucose Monitors (Glucometers)

Capillary blood glucose monitoring involves finger pricking to get a small amount of whole blood that is applied to a test strip, which is analyzed by a small hand-held device that quantifies the glucose concentration. Results from glucose meters are generally less accurate than measures using laboratory methods. In addition, operator-related errors are common,22,23 though possibly becoming less of a problem.24

#### Continuous glucose monitoring (CGM)

CGM utilizes a minimally invasive device that provides glucose measurements from the subcutaneous tissue every 1–5 minutes. Medical personnel or the patients themselves place a catheter in the patient’s abdominal subcutaneous tissue. The catheter contains a small electrode (sensor, probe) which is attached to a small plastic disk about the size of a dime. The disk is taped to the skin to hold the sensor in place. The sensor continuously measures glucose in the patient’s subcutaneous tissue. The glucose values are stored in a separate monitor, which collects 288 readings a day or 864 readings over 72 hours.

In its original form, the patient did not have access to real time glucose values, but more recently, devices that provide real time data to patient have become available. All measurement information can be imported to a computer for storage and analysis. Currently, CGM devices are used to provide glucose trends over a 3 day period and they are approved for use in conjunction with traditional glucometers. In fact, obtaining blood glucose values 2–4 times a day using a blood glucometer is required to calibrate the CGM device. Although CGM does not replace traditional glucometers, it does provide much more information compared to SMBG alone. Future development in this technology should allow CGM devices to work together with insulin pumps and function as an external beta islet cell with ability to detect glucose levels and adjust insulin delivery to maintain euglycemia with avoidance of symptomatic glycemic excursions. However, currently, CGM has been studied primarily in children with type 1 diabetes. It is unclear whether CGM provides added value to traditional SMBG, though at the time of this report, studies have been reported only in devices that do not provide real time data.25–27

#### Glucowatch®

Another noninvasive device, Glucowatch®, uses reverse iontophoresis to measure glucose levels through the skin. The device is capable of providing up to six painless glucose measurements per hour for 13 hours. However, the device requires calibration with a fingerstick blood glucose measurement.28,29

## Evidence on monitoring of glycemia for type 1 diabetes

Based on the DCCT results11 and other smaller experimental or observations studies,30–35 SMBG is recognized to be fundamental in patients with type 1 diabetes for achieving and maintaining the near normal glycemia required to prevent or delay the microvascular complications of the disease. However, there is no evidence that any intervention, including management with SMBG per se, can reverse microvascular disease. SMBG provides real-time feedback including information on the effect of daily activities (eating, activity etc) on glycemia and the presence of transient glycemic excursions, thereby allowing patients with type 1 diabetes to modify their lifestyle and apply short-term adjustments in insulin therapy to avoid symptomatic hyper- or hypoglycemia. Frequent SMBG testing is therefore a well-established management plan for patients with type 1 diabetes especially among those aiming for tight glycemic control who are at highest risk for severe hypoglycemia. Professional organizations36–39 recommend frequent (three times or more) daily SMBG for type 1 diabetics.

Of potential concern, when tightened glycemic control is achieved, there may be an increased risk of severe hypoglycemia episodes. SMBG can be prohibitively expensive for many patients40 as strips cost about $0.70 each.

## Evidence for intensive glycemic control for type 1 diabetes

Based on results from DCCT11, it is currently accepted that patients with type 1 diabetes need to achieve blood glucose levels as close to normal as possible to prevent the development of diabetes-specific microvascular complications. In the DCCT trial, intensive treatment (HbA1c 7.3% vs. 9.1%) reduced the development of retinopathy by 76 percent (89 percent among those with duration of diabetes of less than 2.5 years), nephropathy by 56 percent and neuropathy by 69 percent.41 In type 1 diabetes, for every percentage point drop in HbA1c blood test results (e.g., from 8% to 7%) there is a 40 and 25 percent reduction in the risk of retinopathy and nephropathy respectively.42,43 However, there is no evidence to suggest that microvascular disease improves with intensive glycemic control.

Although there is epidemiologic evidence linking chronic hyperglycemia to increased risk for macrovascular complications, there is limited evidence that tight glycemic control reduces the development or progression of cardiovascular disease in patients with type 1 diabetes. Recently, in the observational followup study to the DCCT, it was shown that participants originally assigned to tight glycemic control had a reduction in cardiovascular disease by 42 percent over an 11-year followup period.44

The following systematic review summarizes and assesses the applicability of the larger published studies related to both intensive glycemic control and SMBG in patients with type 2 diabetes mellitus to the nondialysis-dependent Medicare population.