# List of Rejected Articles

Three year prospective study of visual function and retinopathy in diabetics with improved glycaemic control. Diabetic Retinopathy Study Group St Thomas’ Hospital. Eye. 1987. UI 2457519. (Sample size too small).
U. K. prospective diabetes study 16. Overview of 6 years’ therapy of type II diabetes: a progressive disease. U. K. Prospective Diabetes Study Group. [erratum appears in Diabetes 1996 Nov;45(11):1655]. Diabetes. 1995. Nov. UI 7589820. (Duplicate publication, no additional information).
Effect of intensive diabetes treatment on the development and progression of long-term complications in adolescents with insulin-dependent diabetes mellitus: Diabetes Control and Complications Trial. Diabetes Control and Complications Trial Research Group. Journal of Pediatrics. 1994. Aug. UI 8040759. (Children).
The effect of intensive diabetes therapy on measures of autonomic nervous system function in the Diabetes Control and Complications Trial (DCCT). Diabetologia. 1998. Apr. UI 9562345. (Type 1 DM).
Abraira C, Duckworth W, McCarren M, Emanuele N, Arca D, Reda D, Henderson W. VA Cooperative Study of Glycemic Control and Complications in Diabetes Mellitus Type. Design of the cooperative study on glycemic control and complications in diabetes mellitus type 2: Veterans Affairs Diabetes Trial. Journal of Diabetes & its Complications. 2003. Nov. UI 14583175. (Duplicate publication, no additional information).
Alaveras AE, Thomas SM, Sagriotis A, Viberti GC. Promoters of progression of diabetic nephropathy: the relative roles of blood glucose and blood pressure control. Nephrology Dialysis Transplantation. 1997. UI 9269705. (Retrospective).
Allen BT, DeLong ER, Feussner JR. Impact of glucose self-monitoring on non-insulin-treated patients with type II diabetes mellitus. Randomized controlled trial comparing blood and urine testing. Diabetes Care. 1990. Oct. UI 2170088. (Sample size too small).
Aspinall PA, Kinnear PR, Duncan LJ, Clarke BF. Prediction of diabetic retinopathy from clinical variables and color vision data. Diabetes Care. 1983. Mar. UI 6851807. (Not intervention or predictor of interest).
Bishop JR, Moul JW, Sihelnik SA, Peppas DS, Gormley TS, McLeod DG. Use of glycosylated hemoglobin to identify diabetics at high risk for penile periprosthetic infections. Journal of Urology. 1992. Feb. UI 1732600. (Sample size too small).
Blonde L, Ginsberg BH, Horn S, Hirsch IB, James B, Mulcahy K, Nettles A, Smout R, Wright H. Frequency of blood glucose monitoring in relation to glycemic control in patients with type 2 diabetes. Diabetes Care. 2002;25(1):245-6. Jan. UI 11772926. (Letter). [pmid: 11772926].
Bode BW, Schwartz S, Stubbs HA, Block JE. Glycemic characteristics in continuously monitored patients with type 1 and type 2 diabetes: normative values. Diabetes Care. 2005. Oct. UI 16186263. (Determine CGM normative value).
Bowker SL, Mitchell CG, Majumdar SR, Toth EL, Johnson JA. Lack of insurance coverage for testing supplies is associated with poorer glycemic control in patients with type 2 diabetes. CMAJ Canadian Medical Association Journal. 2004. Jul. 6. UI 15238494. (Retrospective).
Brunetti P, Bueti A, Antonella MA, Calabrese G, Fabietti PG, Santeusanio F, Massi BM. Metabolic effects of intensified insulin therapy. Experimental & Clinical Endocrinology. 1984. Apr. UI 6373314. (Type 1 DM).
Burge MR. Lack of compliance with home blood glucose monitoring predicts hospitalization in diabetes. Diabetes Care. 2001. Aug. UI 11473098. (Letter).
Chan WB, Chan JC, Chow CC, Yeung VT, So WY, Li JK, Ko GT, Ma RC, Cockram CS. Glycaemic control in type 2 diabetes: the impact of body weight, beta-cell function and patient education. Qjm. 2000. Mar. UI 10751238. (Crosssectional).
Chase HP, Jackson WE, Hoops SL, Cockerham RS, Archer PG, O’Brien D. Glucose control and the renal and retinal complications of insulin-dependent diabetes. JAMA. 1989. Feb. 24. UI 2915437. (Type 1 DM).
Chico A, Vidal-Rios P, Subira M, Novials A. The continuous glucose monitoring system is useful for detecting unrecognized hypoglycemias in patients with type 1 and type 2 diabetes but is not better than frequent capillary glucose measurements for improving metabolic control. Diabetes Care. 2003. Apr. UI 12663589. (Sample size too small).
Cohen M, Zimmet P. Self-monitoring of blood glucose levels in non-insulin-dependent diabetes mellitus. Medical Journal of Australia. 1983. Oct. 15. UI 6353187. (Duration too short).
Cox D, Gonder-Frederick L, Polonsky W, Schlundt D, Julian D, Clarke W. A multicenter evaluation of blood glucose awareness training-II. Diabetes Care. 1995. Apr. UI 7497863. (Not intervention or predictor of interest).
Cox DJ, Gonder-Frederick L, Julian D, Cryer P, Lee JH, Richards FE, Clarke W. Intensive versus standard blood glucose awareness training (BGAT) with insulin-dependent diabetes: mechanisms and ancillary effects. Psychosomatic Medicine. 1991. Jul. UI 1924656. (Sample size too small).
Cox DJ, Gonder-Frederick L, Julian DM, Clarke W. Long-term follow-up evaluation of blood glucose awareness training. Diabetes Care. 1994. Jan. UI 8112183. (Not intervention or predictor of interest).
Dorchy H, Roggemans MP, Willems D. Glycated hemoglobin and related factors in diabetic children and adolescents under 18 years of age: a Belgian experience. Diabetes Care. 1997. Jan. UI 9028684. (Children).
Evans JM, Newton RW, Ruta DA, MacDonald TM, Stevenson RJ, Morris AD. Frequency of blood glucose monitoring in relation to glycaemic control: observational study with diabetes database. BMJ. 1999;319(7202):83-6. Jul. 10. UI 10398627. (Retrospective). [pmid: 10398627].
Farmer A, Wade A, French DP, Goyder E, Kinmonth AL, Neil A. The DiGEM trial protocol--a randomised controlled trial to determine the effect on glycaemic control of different strategies of blood glucose self-monitoring in people with type 2 diabetes [ISRCTN47464659]. BMC Family Practice. 2005. Jun. 16. UI 15960852. (Protocol).
Feldt-Rasmussen B. The development of nephropathy in insulin-dependent diabetes mellitus is associated with poor glycemic control. Transplantation Proceedings. 1994. Apr. UI 8171466. (Sample size too small).
Franciosi M, Pellegrini F, De BG, Belfiglio M, Cavaliere D, Di NB, Greenfield S, Kaplan SH, Sacco M, Tognoni G, Valentini M, Nicolucci A. QuED Study Group. The impact of blood glucose self-monitoring on metabolic control and quality of life in type 2 diabetic patients: an urgent need for better educational strategies. Diabetes Care. 2001;24(11):1870-7. Nov. UI 11679449. (Crosssectional). [pmid: 11679449].
Gallichan MJ. Self-monitoring by patients receiving oral hypoglycaemic agents: a survey and a comparative trial. Practical Diabetes. 1994;11:28-30. Not PubMed. (Retrospective).
Gardner DF, Eastman BG, Mehl TD, Merimee TJ. Effect of psychosocial factors on success in a program of self-glucose monitoring. Diabetes Research. 1985. Mar. UI 4042533. (Sample size too small).
Gebhart SS, Wheaton RN, Mullins RE, Austin GE. A comparison of home glucose monitoring with determinations of hemoglobin A1c, total glycated hemoglobin, fructosamine, and random serum glucose in diabetic patients. Archives of Internal Medicine. 1991;151(6):1133-7. Jun. UI 2043015. (Sample size too small). [pmid: 2043015].
Gilden JL, Casia C, Hendryx M, Singh SP. Effects of self-monitoring of blood glucose on quality of life in elderly diabetic patients. Journal of the American Geriatrics Society. 1990. May. UI 2332571. (Sample size too small).
Gordon D, Semple CG, Paterson KR. Do different frequencies of self-monitoring of blood glucose influence control in type 1 diabetic patients?. Diabetic Medicine. 1991. Aug. UI 1833122. (Sample size too small).
Gray A, Raikou M, McGuire A, Fenn P, Stevens R, Cull C, Stratton I, Adler A, Holman R, Turner R. Cost effectiveness of an intensive blood glucose control policy in patients with type 2 diabetes: economic analysis alongside randomised controlled trial (UKPDS 41). United Kingdom Prospective Diabetes Study Group. BMJ. 2000. May. 20. UI 10818026. (Duplicate publication, no additional information).
Gross TM, Bode BW, Einhorn D, Kayne DM, Reed JH, White NH, Mastrototaro JJ. Performance evaluation of the MiniMed continuous glucose monitoring system during patient home use. Diabetes Technology & Therapeutics. 2000. UI 11467320. (Sample size too small).
Guillausseau PJ. Monitoring of metabolic control in patients with non-insulin-dependent diabetes mellitus on oral hypoglycaemic agents: value of evening blood glucose determination. Diabetic Medicine. 1997;14(9):798-802. Sep. UI 9300232. (Not intervention or predictor of interest). [pmid: 9300232].
Hadden DR, Blair AL, Wilson EA, Boyle DM, Atkinson AB, Kennedy AL, Buchanan KD, Merrett JD, Montgomery DA, Weaver JA. Natural history of diabetes presenting age 40–69 years: a prospective study of the influence of intensive dietary therapy. Quarterly Journal of Medicine. 1986. Jun. UI 3749450. (Not intervention or predictor of interest).
Hadden DR, Patterson CC, Atkinson AB, Kennedy L, Bell PM, McCance DR, Weaver JA. Macrovascular disease and hyperglycaemia: 10-year survival analysis in Type 2 diabetes mellitus: the Belfast Diet Study. Diabetic Medicine. 1997. Aug. UI 9272593. (Not intervention or predictor of interest).
Harris MI. National Health and Nutrition Examination Survey (NHANES III). Frequency of blood glucose monitoring in relation to glycemic control in patients with type 2 diabetes. Diabetes Care. 2001;24(6):979-82. Jun. UI 11375356. (Crosssectional). [pmid: 11375356].
Harrower AD, Gilmour GA. The assessment of diabetic control in insulin-independent patients. Scottish Medical Journal. 1982. Jan. UI 7063829. (Not intervention or predictor of interest).
Hartemann-Heurtier A, Sachon C, Masseboeuf N, Corset E, Grimaldi A. Functional intensified insulin therapy with short-acting insulin analog: effects on HbA1c and frequency of severe hypoglycemia. An observational cohort study. Diabetes & Metabolism. 2003. Feb. UI 12629448. (Type 1 DM).
Hellman R, Regan J, Rosen H. Effect of intensive treatment of diabetes of the risk of death or renal failure in NIDDM and IDDM. Diabetes Care. 1997;20(3):258-64. 1997. UI 9051368. (Sample size too small for population, intervention, and outcomes of interest). [pmid: 9051368].
Hendra TJ, Taylor CD. A randomised trial of insulin on well-being and carer strain in elderly type 2 diabetic subjects. Journal of Diabetes & its Complications. 2004. May. UI 15145325. (Sample size too small).
Henricsson M, Nilsson A, Janzon L, Groop L. The effect of glycaemic control and the introduction of insulin therapy on retinopathy in non-insulin-dependent diabetes mellitus. Diabetic Medicine. 1997. Feb. UI 9047089. (Not intervention or predictor of interest).
Hewer W, Mussell M, Rist F, Kulzer B, Bergis K. Short-term effects of improved glycemic control on cognitive function in patients with type 2 diabetes. Gerontology. 2003. Mar. UI 12574669. (Duration too short).
Hoffman RM, Shah JH, Wendel CS, Duckworth WC, Adam KD, Bokhari SU, Dalton C, Murata GH. Diabetes Outcome in Veterans Study. Evaluating once- and twice-daily self-monitored blood glucose testing strategies for stable insulin-treated patients with type 2 diabetes : the diabetes outcomes in veterans study. Diabetes Care. 2002. Oct. UI 12351471. (Duration too short).
Holman RR, Dornan TL, Mayon-White V, Howard-Williams J, Orde-Peckar C, Jenkins L, Steemson J, Rolfe R, Smith B, Barbour D, McPherson K, Poon P, Rizza C, Mann JI, Knight AH, Bron AJ, Turner RC. Prevention of deterioration of renal and sensory-nerve function by more intensive management of insulin-dependent diabetic patients. A two-year randomised prospective study. Lancet. 1983. Jan. 29. UI 6130244. (Type 1 DM).
Horton ES, Clinkingbeard C, Gatlin M, Foley J, Mallows S, Shen S. Nateglinide alone and in combination with metformin improves glycemic control by reducing mealtime glucose levels in type 2 diabetes. Diabetes Care. 2000. Nov. UI 11092289. (Not intervention or predictor of interest).
Hotta N, Kawamori R, Sano T, Kakuta H, Kamada T, Sakamoto N. Diabetic neuropathy: effects of intensified glycaemic control with multiple insulin injections. Diabetic Medicine. 1993. UI 8334854. (Sample size too small).
Houtzagers CM, Berntzen PA, van der SH, van Maarschalkerweerd WW, Lanting P, Boen-Tan I, Heine RJ, van d. Efficacy and acceptance of two intensified conventional insulin therapy regimens: a long-term cross-over comparison. Diabetic Medicine. 1989. Jul. UI 2527678. (Sample size too small).
Jensen-Urstad KJ, Reichard PG, Rosfors JS, Lindblad LE, Jensen-Urstad MT. Early atherosclerosis is retarded by improved long-term blood glucose control in patients with IDDM. Diabetes. 1996. Sep. UI 8772731. (Type 1 DM).
Karter AJ, Ackerson LM, Darbinian JA, D’Agostino RB, Ferrara A, Liu J, Selby JV. Self-monitoring of blood glucose levels and glycemic control: the Northern California Kaiser Permanente Diabetes registry. American Journal of Medicine. 2001. Jul. UI 11448654. (Retrospective).
Kawachi I, Conaglen JV, Bryson LR, Kilpatrick JA. An assessment of home monitoring of blood glucose levels in Dunedin. New Zealand Medical Journal. 1983. Aug. 24. UI 6348610. (Sample size too small).
Kawamori R, Kamada T. Determination of the glycemic threshold for the regression or prevention of diabetic microangiopathies, and the insulin injection regimen to establish strict glycemic control in NIDDM. Japanese Journal of Medicine. 1991. Nov. UI 1798230. (Sample size too small).
Klein CE, Oboler SK, Prochazka A, Oboler S, Frank M, Glugla M, Winters S. Home blood glucose monitoring: effectiveness in a general population of patients who have non-insulin-dependent diabetes mellitus. Journal of General Internal Medicine. 1993. Nov. UI 8289098. (Retrospective).
Kovatchev BP, Cox DJ, Straume M, Farhy LS. Association of self-monitoring blood glucose profiles with glycosylated hemoglobin in patients with insulin-dependent diabetes. Methods in Enzymology. 2000. UI 10909069. (Test accuracy study [meter]).
Laakso M. Glycemic control and the risk for coronary heart disease in patients with non-insulin-dependent diabetes mellitus. The Finnish studies. Annals of Internal Medicine. 1996. Jan. 1. UI 8554204. (Review).
Ladyzynski P, Wojcicki JM, Jozwicka E, Blachowicz J, Krzymien J. Reliability of blood glucose self-monitoring and its influence on glycemic control in highly motivated type 1 diabetic patients. Diabetes Care. 1999. May. UI 10332696. (Sample size too small).
Lam KS, Ma JT, Chan EY, Yeung RT. Sustained improvement in diabetic control on long-term self-monitoring of blood glucose. Diabetes Research & Clinical Practice. 1986. Jun. UI 3527625. (Sample size too small).
Lazar HL, Chipkin SR, Fitzgerald CA, Bao Y, Cabral H, Apstein CS. Tight glycemic control in diabetic coronary artery bypass graft patients improves perioperative outcomes and decreases recurrent ischemic events. Circulation. 2004. Mar. 30. UI 15006999. (Not intervention or predictor of interest).
Levin SR, Coburn JW, Abraira C, Henderson WG, Colwell JA, Emanuele NV, Nuttall FQ, Sawin CT, Comstock JP, Silbert CK. Effect of intensive glycemic control on microalbuminuria in type 2 diabetes. Veterans Affairs Cooperative Study on Glycemic Control and Complications in Type 2 Diabetes Feasibility Trial Investigators. Diabetes Care. 2000. Oct. UI 11023140. (Duplicate publication, no additional information).
Lovestam-Adrian M, Agardh CD, Torffvit O, Agardh E. Diabetic retinopathy, visual acuity, and medical risk indicators: a continuous 10-year follow-up study in Type 1 diabetic patients under routine care. Journal of Diabetes & its Complications. 2001. Nov. UI 11711321. (Type 1 DM).
Maluf G. Laboratory testing vs at-home glucose readings in monitoring diabetes. American Clinical Laboratory. 2001. Sep. UI 11586937. (Sample size too small).
Martin BJ, Yong RE, Kesson CM. Home monitoring of blood glucose in elderly non-insulin-dependent diabetics. Practical Diabetes. 1986;3:37. Not PubMed. (Not intervention or predictor of interest).
Martin S, Schneider B, Heinemann L, Lodwig V, Kurth HJ, Kolb H, Scherbaum WA. Self-monitoring of blood glucose in type 2 diabetes and long-term outcome: an epidemiological cohort study. Diabetologia. 2006. Feb. UI 16362814. (Retrospective).
Meier JL, Swislocki AL, Lopez JR, Noth RH, Bartlebaugh P, Siegel D. Reduction in self-monitoring of blood glucose in persons with type 2 diabetes results in cost savings and no change in glycemic control. American Journal of Managed Care. 2002. Jun. UI 12068962. (Retrospective).
Menzel R, Brunstein U, Conde N, Bombor H, Albrecht G, Jutzi E. Methods and effects of improved conventional insulin treatment in labile insulin-dependent diabetes (IDDM). Experimental & Clinical Endocrinology. 1984. Apr. UI 6373317. (Type 1 DM).
Metzger M, Leibowitz G, Wainstein J, Glaser B, Raz I. Reproducibility of glucose measurements using the glucose sensor. Diabetes Care. 2002. Jul. UI 12087017. (Sample size too small).
Meyer L, Grulet H, Guerci B, Gross A, Durlach V, Leutenegger M. Short-term intensive insulin therapy in insulin-requiring diabetes: effectiveness and factors predicting success. Diabetes & Metabolism. 1997. Feb. UI 9059770. (No outcome of interest).
Muchmore DB, Springer J, Miller M. Self-monitoring of blood glucose in overweight type 2 diabetic patients. Acta Diabetologica. 1994. Dec. UI 7888692. (Sample size too small).
Muhlhauser I, Sawicki PT, Blank M, Overmann H, Bender R, Berger M. Prognosis of persons with type 1 diabetes on intensified insulin therapy in relation to nephropathy. Journal of Internal Medicine. 2000. Oct. UI 11086645. (Type 1 DM).
Murata GH, Duckworth WC, Shah JH, Wendel CS, Hoffman RM. Sources of glucose variability in insulin-treated type 2 diabetes: the Diabetes Outcomes in Veterans Study (DOVES). Clinical Endocrinology. 2004. Apr. UI 15049959. (No primary data).
Murata GH, Hoffman RM, Shah JH, Wendel CS, Duckworth WC. A probabilistic model for predicting hypoglycemia in type 2 diabetes mellitus: The Diabetes Outcomes in Veterans Study (DOVES). Archives of Internal Medicine. 2004. Jul. 12. UI 15249354. (No primary data).
Murata GH, Shah JH, Hoffman RM, Wendel CS, Adam KD, Solvas PA, Bokhari SU, Duckworth WC. Diabetes Outcomes in Veterans Study (DOVES). Intensified blood glucose monitoring improves glycemic control in stable, insulin-treated veterans with type 2 diabetes: the Diabetes Outcomes in Veterans Study (DOVES). Diabetes Care. 2003. Jun. UI 12766106. (Duration too short).
Murata GH, Shah JH, Wendel CS, Hoffman RM, Adam KD, Bokhari SU, Solvas PA, Duckworth WC. Risk factor management in stable, insulin-treated patients with Type 2 diabetes: the Diabetes Outcomes in Veterans Study. Journal of Diabetes & its Complications. 2003. Jul. UI 12810241. (Duplicate publication, no additional information).
Nathan DM, McKitrick C, Larkin M, Schaffran R, Singer DE. Glycemic control in diabetes mellitus: have changes in therapy made a difference?. American Journal of Medicine. 1996. Feb. UI 8629649. (Retrospective).
Nerenz DR, Repasky DP, Whitehouse FW, Kahkonen DM. Ongoing assessment of health status in patients with diabetes mellitus. Medical Care. 1992. May. UI 1583926. (<50% Type 2).
Newman WP, Laqua D, Engelbrecht D. Impact of glucose self-monitoring on glycohemoglobin values in a veteran population. Archives of Internal Medicine. 1990. Jan. UI 2297280. (Sample size too small).
Nicer T, Mardarowicz G, Lopatynski J. Usefulness of glucose levels determination with glucometer in epidemiologic research. Annales Universitatis Mariae Curie-Sklodowska - Sectio d - Medicina. 2003. UI 15315026. (Not intervention or predictor of interest).
Nordfeldt S, Ludvigsson J. Adverse events in intensively treated children and adolescents with type 1 diabetes. Acta Paediatrica. 1999. Nov. UI 10591418. (Children).
Nyomba BL, Berard L, Murphy LJ. The cost of self-monitoring of blood glucose is an important factor limiting glycemic control in diabetic patients. Diabetes Care. 2002. Jul. UI 12087028. (Letter).
Nyomba BL, Berard L, Murphy LJ. Facilitating access to glucometer reagents increases blood glucose self-monitoring frequency and improves glycaemic control: a prospective study in insulin-treated diabetic patients. Diabetic Medicine. 2004. Feb. UI 14984447. (<50% Type 2).
Oki JC, Flora DL, Isley WL. Frequency and impact of SMBG on glycemic control in patients with NIDDM in an urban teaching hospital clinic. Diabetes Educator. 1997;23(4):419-24. Jul. UI 9305007. (Crosssectional). [pmid: 9305007].
Ose H, Fukui M, Kitagawa Y, Hirata C, Ichio N, Kadono M, Mogami S, Onishi M, Ichida Y, Nakajima T, Hasegawa G, Yoshikawa T, Nakamura N. Efficacy of glimepiride in patients with poorly controlled insulin-treated type 2 diabetes mellitus. Endocrine Journal. 2005. Oct. UI 16284434. (Retrospective).
Ostgren CJ, Lindblad U, Melander A, Rastam L. Survival in patients with type 2 diabetes in a Swedish community: skaraborg hypertension and diabetes project. Diabetes Care. 2002. Aug. UI 12145224. (Not intervention or predictor of interest).
Patrick AW, Gill GV, MacFarlane IA, Cullen A, Power E, Wallymahmed M. Home glucose monitoring in type 2 diabetes: is it a waste of time?. Diabetic Medicine. 1994. Jan. UI 8181255. (Crosssectional).
Peel E, Parry O, Douglas M, Lawton J. Blood glucose self-monitoring in non-insulin-treated type 2 diabetes: a qualitative study of patients’ perspectives. British Journal of General Practice. 2004. Mar. UI 15006123. (Sample size too small).
Penfold J, Chase HP, Marshall G, Walravens CF, Walravens PA, Garg SK. Final adult height and its relationship to blood glucose control and microvascular complications in IDDM. Diabetic Medicine. 1995. Feb. UI 7743759. (Type 1 DM).
Queale WS, Seidler AJ, Brancati FL. Glycemic control and sliding scale insulin use in medical inpatients with diabetes mellitus. Archives of Internal Medicine. 1997. Mar. 10. UI 9066459. (Duration too short).
Reichard P, Berglund B, Britz A, Cars I, Nilsson BY, Rosenqvist U. Intensified conventional insulin treatment retards the microvascular complications of insulin-dependent diabetes mellitus (IDDM): the Stockholm Diabetes Intervention Study (SDIS) after 5 years. Journal of Internal Medicine. 1991. Aug. UI 1865159. (Type 1 DM).
Reichard P, Britz A, Carlsson P, Cars I, Lindblad L, Nilsson BY, Rosenqvist U. Metabolic control and complications over 3 years in patients with insulin dependent diabetes (IDDM): the Stockholm Diabetes Intervention Study (SDIS). Journal of Internal Medicine. 1990. Nov. UI 2254723. (Type 1 DM).
Reichard P, Britz A, Cars I, Nilsson BY, Sobocinsky-Olsson B, Rosenqvist U. The Stockholm Diabetes Intervention Study (SDIS): 18 months’ results. Acta Medica Scandinavica. 1988. UI 3048052. (Type 1 DM).
Reichard P, Britz A, Rosenqvist U. Intensified conventional insulin treatment and neuropsychological impairment. BMJ. 1991. Dec. 7. UI 1773148. (Type 1 DM).
Reichard P, Nilsson BY, Rosenqvist U. The effect of long-term intensified insulin treatment on the development of microvascular complications of diabetes mellitus. New England Journal of Medicine. 1993. Jul. 29. UI 8147960. (Type 1 DM).
Reichard P, Rosenqvist U. Nephropathy is delayed by intensified insulin treatment in patients with insulin-dependent diabetes mellitus and retinopathy. Journal of Internal Medicine. 1989. Aug. UI 2671247. (Type 1 DM).
Rindone JP, Austin M, Luchesi J. Effect of home blood glucose monitoring on the management of patients with non-insulin dependent diabetes mellitus in the primary care setting. American Journal of Managed Care. 1997. Sep. UI 10178482. (Retrospective).
Rosenstock J, Challis P, Strowig S, Raskin P. Improved diabetes control reduces skeletal muscle capillary basement membrane width in insulin-dependent diabetes mellitus. Diabetes Research & Clinical Practice. 1988. Feb. 19. UI 3359916. (Type 1 DM).
Rosenstock J, Friberg T, Raskin P. Effect of glycemic control on microvascular complications in patients with type I diabetes mellitus. American Journal of Medicine. 1986. Dec. UI 3541587. (Type 1 DM).
Schiel R, Muller UA, Rauchfub J, Sprott H, Muller R. Blood-glucose self-monitoring in insulin treated type 2 diabetes mellitus a cross-sectional study with an intervention group. Diabetes & Metabolism. 1999. Sep. UI 10566123. (Crosssectional).
Schiel R, Muller UA, Ulbrich S. Long-term efficacy of a 5-day structured teaching and treatment programme for intensified conventional insulin therapy and risk for severe hypoglycemia. Diabetes Research & Clinical Practice. 1997. Feb. UI 9113474. (Type 1 DM).
Schiel R, Ulbrich S, Muller UA. Quality of diabetes care, diabetes knowledge and risk of severe hypoglycaemia one and four years after participation in a 5-day structured treatment and teaching programme for intensified insulin therapy. Diabetes & Metabolism. 1998. Dec. UI 9932217. (Type 1 DM).
Schiffrin A, Belmonte M. Multiple daily self-glucose monitoring: its essential role in long-term glucose control in insulin-dependent diabetic patients treated with pump and multiple subcutaneous injections. Diabetes Care. 1982;5(5):479-84. Sep. UI 6765224. (Sample size too small). [pmid: 6765224].
Scobie IN, Tey BH, Bowden VK, Judd SL, Lowy C, Sonksen PH. Self monitoring of blood glucose. A study of longer term experience in diabetic patients. Diabete et Metabolisme. 1984. May. UI 6745479. (Letter).
Seppala B, Seppala M, Ainamo J. A longitudinal study on insulin-dependent diabetes mellitus and periodontal disease. Journal of Clinical Periodontology. 1993. Mar. UI 8450080. (Type 1 DM).
Shaw KM, Wheeley MS, Campbell DB, Ward JD. Home blood glucose monitoring in non-insulin-dependent diabetics: the effect of gliclazide on blood glucose and weight control, a multicentre trial. Diabetic Medicine. 1985. Nov. UI 2951123. (Not intervention or predictor of interest).
Solders G, Thalme B, guirre-Aquino M, Brandt L, Berg U, Persson A. Nerve conduction and autonomic nerve function in diabetic children. A 10-year follow-up study. Acta Paediatrica. 1997. Apr. UI 9174220. (Children).
Sonksen PH, Judd SL, Lowy C. Home monitoring of blood-glucose. Method for improving diabetic control. Lancet. 1978;1(8067):729-32. Apr. 8. UI 76745. (Retrospective). [pmid: 76745].
Soumerai SB, Mah C, Zhang F, Adams A, Barton M, Fajtova V, Ross-Degnan D. Effects of health maintenance organization coverage of self-monitoring devices on diabetes self-care and glycemic control. Archives of Internal Medicine. 2004;164(6):645-52. Mar. 22. UI 15037493. (Retrospective). [pmid: 15037493].
Tajima N, Yamada C, Asukata I, Yamamoto K, Hokari M, Sakai T. Pilots with non-insulin-dependent diabetes mellitus can self-monitor their blood glucose. Aviation Space & Environmental Medicine. 1989;60(5):457-9. May. UI 2730490. (Sample size too small).
Tanenberg R, Bode B, Lane W, Levetan C, Mestman J, Harmel AP, Tobian J, Gross T, Mastrototaro J. Use of the Continuous Glucose Monitoring System to guide therapy in patients with insulin-treated diabetes: a randomized controlled trial. Mayo Clinic Proceedings. 2004. Dec. UI 15595336. (Type 1 DM [90%]).
Terent A, Hagfall O, Cederholm U. The effect of education and self-monitoring of blood glucose on glycosylated hemoglobin in type I diabetes. A controlled 18-month trial in a representative population. Acta Medica Scandinavica. 1985. UI 3883704. (Sample size too small).
Turner R, Cull C, Holman R. United Kingdom Prospective Diabetes Study 17: a 9-year update of a randomized, controlled trial on the effect of improved metabolic control on complications in non-insulin-dependent diabetes mellitus. Annals of Internal Medicine. 1996. Jan. 1. UI 8554206. (Duplicate publication, no additional information).
Tzamaloukas AH, Murata GH, Zager PG, Eisenberg B, Avasthi PS. The relationship between glycemic control and morbidity and mortality for diabetics on dialysis. ASAIO Journal. 1993. Oct. UI 8123921. (Dialysis).
Uusitupa M, Laitinen J, Siitonen O, Vanninen E, Pyorala K. The maintenance of improved metabolic control after intensified diet therapy in recent type 2 diabetes. Diabetes Research & Clinical Practice. 1993. Mar. UI 8319521. (Sample size too small).
Waldhausl W, Howorka K, Derfler K, Bratusch-Marrain PR, Holler C, Zyman H, Freyler H. Failure and efficacy of insulin therapy in insulin dependent (type I) diabetic patients. Acta Diabetologica Latina. 1985. Oct. UI 3914155. (Type 1 DM).
Walford S, Gale EA, Allison SP, Tattersall RB. Self-monitoring of blood-glucose. Improvement of diabetic control. Lancet. 1978;1(8067):732-5. Apr. 8. UI 76746. (No outcome of interest). [pmid: 76746].
Weinberger M, Kirkman MS, Samsa GP, Cowper PA, Shortliffe EA, Simel DL, Feussner JR. The relationship between glycemic control and health-related quality of life in patients with non-insulin-dependent diabetes mellitus. Medical Care. 1994. Dec. UI 7967857. (Not intervention or predictor of interest).
Weinberger M, Kirkman MS, Samsa GP, Shortliffe EA, Landsman PB, Cowper PA, Simel DL, Feussner JR. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. Journal of General Internal Medicine. 1995. Feb. UI 7730940. (Not intervention or predictor of interest).
Wen L, Parchman ML, Linn WD, Lee S. Association between self-monitoring of blood glucose and glycemic control in patients with type 2 diabetes mellitus. American Journal of Health-System Pharmacy. 2004. Nov. 15. UI 15581263. (Retrospective).
Wieland LD, Vigil JM, Hoffman RM, Janis LW. Relationship between home glucose testing and hemoglobin Alc in type II diabetes patients. American Journal of Health-System Pharmacy. 1997. May. 1. UI 9143655. (Retrospective).
Wing RR, Epstein LH, Nowalk MP, Scott N, Koeske R, Hagg S. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. American Journal of Medicine. 1986. Nov. UI 3535493. (Sample size too small).
Wolffenbuttel BH, Sels JP, Rondas-Colbers GJ, Menheere PP, Nieuwenhuijzen Kruseman AC. Comparison of different insulin regimens in elderly patients with NIDDM. Diabetes Care. 1996. Dec. UI 8941458. (Not intervention or predictor of interest).
Worth R, Home PD, Johnston DG, Anderson J, Ashworth L, Burrin JM, Appleton D, Binder C, Alberti KG. Intensive attention improves glycaemic control in insulin-dependent diabetes without further advantage from home blood glucose monitoring: results of a controlled trial. British Medical Journal Clinical Research Ed. 1982. Oct. 30. UI 6812820. (Sample size too small).
Yoshida Y, Hagura R, Hara Y, Sugasawa G, Akanuma Y. Risk factors for the development of diabetic retinopathy in Japanese type 2 diabetic patients. Diabetes Research & Clinical Practice. 2001. Mar. UI 11269892. (Not intervention or predictor of interest).
Yu CC, Wu MS, Wu CH, Yang CW, Huang JY, Hong JJ, Fan Chiang CY, Leu ML, Huang CC. Predialysis glycemic control is an independent predictor of clinical outcome in type II diabetics on continuous ambulatory peritoneal dialysis. Peritoneal Dialysis International. 1997. May. UI 9237287. (Dialysis).
Ziegher O, Kolopp M, Louis J, Musse JP, Patris A, Debry G, Drouin P. Self-monitoring of blood glucose and insulin dose alteration in type 1 diabetes mellitus. Diabetes Research & Clinical Practice. 1993. Jul. UI 8253023. (Type 1 DM).