# Results

The search strategy yielded 88 articles. The selection process is described below:

The 23 included reports comprised 16 full reports and 7 abstract-only publications (Table 3). Study designs included two phase III controlled clinical trials (ongoing, three abstract reports), five phase II uncontrolled clinical trials (four trials in eight full reports plus one trial in one abstract), and eight studies of other designs. Four of these studies with other designs evaluated the role of surgery plus imatinib and four were investigating the role of imaging techniques in predicting GIST outcomes. There were several sub-studies of the phase II trials assessing predictors of GIST outcomes–one assessing radiological predictors, four of tumor characteristics, and two of other clinical predictors. All of the adverse events data were derived from the four phase II clinical trials that were published in full reports.

Quality of the studies varied by outcome category. All of the main imatinib efficacy studies published in full were of high quality. Only one of the four imatinib plus surgery studies was of high quality. Two of the four molecular predictor studies were of high quality, with one low quality study and one abstract. Two of five radiological predictor studies were of high quality, with one low quality study and two abstracts. With the exception of the one abstract, all of the studies reported other types of predictors were of high quality. In summary, study quality was generally high, with surgical and radiological studies being the most suspect.

Table 3 Details of included studies

Study # | First Author, Year | Phase | Report type | Quality | Comments
Imatinib efficacy studies
1 | van Oosterom, 2001^6^ | I/II | Full report | 3/5 | Main results
1 | van Oosterom, 2002^45^ | III | Full report | 3/5 | Followup efficacy data for van Oosterom et al. 2001
2 | Demetri, 2002^46^ | II | Full report | 5/5 | Main results
2 | Dagher 2002^43^ | II | Full report | 5/5 | FDA approval summary with review of Demetri et al. 2002 data
2 | Heinrich, 2003^47^ | II | Full report | 6/6 | Follow up efficacy data for Demetri et al. 2002
3 | Verweij, 2003^48^ | II | Full report | 6/6 | Main results
4 | Verweij, 2004^49^ | III | Full report | 6/6 | Main results
4 | Zalcberg, 2004^50^ | II | Abstract | Unk | Followup efficacy data for Verweij et al. 2004
5 | Casali, 2004^51^ | II | Abstract | Unk | Early results of phase II trial
6 | Blay, 2004^52^ | III | Abstract | Unk | Early results of phase III trial
7 | Rankin, 2004^53^ | III | Abstract | Unk | Early results of phase III trial
7 | Patel, 2003^54^ | III | Abstract (published 2003 abstract plus commentary) | Unk | Early results of Rankin et al. 2004 Phase III trial
Imatinib plus surgery efficacy studies
8 | Bumming, 2003^55^ | II | Full report | 4/6 | Main results
9 | Rutkowski, 2003^56^ | Retro | Full report | 1/6 | Main results
10 | Scaife, 2003^57^ | Retro | Full report | 2/5 | Main results
11 | Wu, 2003^58^ | Retro | Full report | 1/6 | Main results
Adverse events/harm
1 | van Oosterom, 2001^6^ | I/II | Full report | 3/5 | Adverse event data reported within main results full report
1 | van Oosterom, 2002^45^ | III | Full report | 3/5 | Follow up adverse event data for van Oosterom et al. 2001
2 | Demetri, 2002^46^ | II | Full report | 5/5 | Adverse event data reported within main results full report
2 | Dagher 2002^43^ | II | Full report | 5/5 | FDA approval summary with review of Demetri et al. 2002 data
3 | Verweij, 2003^48^ | II | Full report | 6/6 | Adverse event data reported within main results full report
4 | Verweij, 2004^49^ | III | Full report | 6/6 | Adverse event data reported within main results full report
Predictors – tumor characteristics
1 | Debiec-Rychter, 2004^59^ | I/II | Full report | 6/6 | Molecular predictors, sub-study of van Oosterom et al. 2001
2 | Frolov, 2003^60^ | II | Full report | 1/6 | Molecular predictors, sub-study of Demetri et al. 2002
2 | Heinrich, 2003^47^ | II | Full report | 6/6 | Molecular predictors, sub-study of Demetri et al. 2002
3 | Verweij, 2003^48^ | II | Full report | 6/6 | Other predictors reported within main results full report
Predictors – radiological findings
1 | Stroobants, 2003^61^ | I/II | Full report | 4/6 | Radiological predictors, sub-study of van Oosterom et al. 2001
12 | Antoch, 2004^62^ | Pros | Full report | 5/5 | Radiological predictors study
13 | Gayed, 2004^63^ | Pros | Full report | 1/5 | Radiological predictors study
14 | Di Giorgi, 2004^64^ | Pros | Abstract | Unk | Radiological predictors study
15 | Laussau, 2004^65^ | Pros | Abstract | Unk | Radiological predictors study
Predictors – other clinical factors
2 | Heinrich, 2003^47^ | II | Full report | 6/6 | Other predictors, sub-study of Demetri et al. 2002
4 | Verweij, 2004^49^ | III | Full report | 6/6 | Other predictors reported within main results full report

Abbreviations: Retro = retrospective; Unk = unknown; Pros = prospective

## Efficacy

### Imatinib Alone for Advanced GIST

There are four completed high quality studies of imatinib alone for the management of unresectable or metastatic CD117-positive GIST (Table 4) involving a total of 1156 patients with GIST. The patient populations were nearly identical except for the studies by van Oosterom et al. and Verweij et al. (2001) which included some patients with non-GIST soft tissue sarcomas (STS). When described, 83–98 percent of patients had prior surgery, 33–71 percent of patients had prior chemotherapy, and 8–24 percent of patients had prior radiotherapy. The average age was 55 with a range of 18–83; 62 percent were male.

The completed trials comprise several different designs. The first is a mixed phase design with a dose escalation phase from 400 mg to 1000 mg and phase III follow through at 800 mg (total N = 40).6, 45 The second is a randomized phase II with patients randomized to 400 or 600 mg daily (total N = 147).43, 46, 47 The third is a standard phase II design evaluating efficacy of 800 mg daily (N = 50).48 The fourth is randomized phase III with patients randomized to 400 or 800 mg daily (total N = 946).49 Followup lasted 9–25 months. There is one incomplete phase II trial reported in abstract form only.51 This trial appears to be a standard phase II with 135 patients (mean age 65, 70 percent male) receiving an unspecified dose of imatinib.

Tumor response was the most consistent outcome reported. In the completed phase II and phase III studies, complete response (CR) rates ranged from 0–6 percent, partial response (PR) rates ranged from 45–67 percent, and stable disease (SD) rates ranged from 19–47 percent. Overall response (CR + PR) was 49–71 percent.

Overall survival (OS), disease-free survival (DFS), event-free survival (EFS), and progression-free survival (PFS) were variably reported. Verweij et al. (2004) had the longest median follow up (760 days), and reported 1 year OS as 85 percent for either the 400 mg/d or 800 mg/d doses and 2 year OS as 69 percent for the 400 mg/d dose and 74 percent for the 800 mg/d dose (p not significant).49 Two-year PFS on that study was 44 percent for the 400 mg/d dose and 50 percent for the 800 mg/d dose (p = 0.026). The study initially described by Demetri et al. in 2002 had a subsequent report by Heinrich et al. in 2003 that reported median follow up of 594 days.46, 47 The OS reported for all patients was 85 percent at 76 weeks, with a median EFS of 17 months.47

Two phase III efficacy studies of imatinib are currently ongoing. Both of these are published in abstract form only. Both compare different dosing regimens of imatinib. Blay and colleagues are testing continuous vs. intermittent imatinib dosing schedules52 and Rankin et al. are testing 400 mg/d vs. 800 mg/d.53 Results are preliminary. The study of 400 mg/d vs. 800 mg/d involved 746 participants and reports 2-year OS at 78 percent (CI 73–82%) for the 400 mg/d group and 73 percent (CI 68–77%) for the 800 mg/d group. The 2-year PFS is 50 percent (CI 45–55 percent) for the 400 mg/d group and 53 percent (CI 47–58 percent) for the 800 mg/d group.

The only significant difference in outcomes identified between different dosing schedules was that seen in the Verweij et al. (2004) study where patients on 800 mg/d have significantly higher PFS rates.49 Two studies have evaluated the potential to increase the dose from 400 mg/d to 800 mg/d in the setting of tumor progression at the lower dose. In a subsequent abstract report of the Verweij et al. (2004) study, 220 of 473 patients on the lower dose of 400 mg/d progressed; 65 percent (143) crossed over to the 800 mg/d dose with 26 percent progression-free at one year.50 Toxicity required dose reductions in 31 percent of those who crossed over to the higher dose. In the ongoing Rankin et al. phase III trial, 164 patients on the lower dose of 400 mg/d progressed; 54 percent (88) crossed over to the 800 mg/d dose with median PFS of 4 months and median OS of 19 months after crossover. The overall interpretation of these studies is that crossover is feasible with some tumor responses.

### Imatinib Plus Surgery

Four studies were identified that reviewed the role of imatinib in peri-surgical settings (Table 5) including neoadjuvant imatinib prior to planned tumor resection, adjuvant imatinib for tumors at high risk of recurrence after complete resection, and palliative imatinib after incomplete surgery. Only one of these was prospective (Bumming 55), while the others were retrospective reviews of prospectively collected registry data. The summary finding from these small lower-quality studies is that neoadjuvant and adjuvant imatinib is feasible. The efficacy is still to be determined.

Table 4 Summary of efficacy of imatinib for GIST

Study ID | Imatinib dose [length of follow up] | No. of patients, age 66), sex | GIST tumor characteristics | Outcomes sought | N | %CR | %PR | %SD | %PD | %NE | Survival/ Other
Phase II
van Oosterom et al., 2001^6^ with followup in: van Oosterom et al., 2002^45^ | 400–1000 mg dose escalation Phase I; 800 mg Phase II [9–13 mo] | 40 pts 53 [29–69] 63% M | 36 had CD117-positive GIST and 4 had non-GIST STS per 2001 report; 35 had CD 117 GIST and 5 had non-GIST STS per 2002 report Liver metastases 75% 60% previous chemotherapy; 10% previous XRT | Tumor response-RECIST CT/PET Toxicity- NCI CTC v2.0 | GIST 36 Non-GIST STS 4 | | 53% | 47% 25% | 11% 75% | | At minimum followup of 9–13 mo, 81% of GIST patients were still on imatinib
Demetri, 2002^46^ with repeated report in: Dagher 2002^43^ and follow up in: Heinrich, 2003^47^ | Randomized between 400 and 600 mg [minimum 9 mo with median 288 dys; Heinrich et al. report with 19 mo followup with median 594d] | 147 pts 54 [18–83] 57% M | All tumors CD117 positive 100% unresectable or metastatic 90% with recurrence at the time of imatinib therapy Prior therapies: 98% Surgery 51% Chemotherapy 15% Radiotherapy | Mortality: K- M Tumor response: MRI/CT RECIST QOL/PM: (ECOG) Adverse events: CTC 2.0 | All 400 mg dose (73) 600 mg dose (74) | 0% 0% 0% | 54% 49% 58% | 28% 32% 24% | 14% 16% 11% | 5% 3% 1% | OS at 76 wks = 85% median EFS = 17 mo
Verweij, 2003^48^ | 800 mg [median followup=13+ mo for GIST pts and 2 mo for non-GIST STS pts] | 51 (27 GIST 24 STS) 53 [21–75] 67% M | GIST = CD 117 positive All advanced, unresectable or metastatic Prior therapies: 88% surgery 24% radiotherapy 71% chemotherapy | Tumor response: RECIST Time to progression | GIST 27 Non-GIST STS 24 | 4% 0% | 67% 0% | 19% 29% | 11% NR | | GIST with 73% DFS at 1 yr
Verweij, 2004^49^ with followup in: Zalcberg, 2004^50^ (abstract) | Randomized between Imatinib 400 mg/d vs. Imatinib 800 mg/d (given as 400 mg twice daily) [median followup 760d] | 946 473 @400 mg/d 59 [49–67] 60% M 473@800 mg/d 60 [49–68] 61% M | GIST = CD 117 positive All advanced, unresectable or metastatic 400 mg qd: 87% surgery 6% radiotherapy 33% chemotherapy 800 mg qd: 83% surgery 8% radiotherapy 33% chemotherapy | Progression free survival-KM Overall survival-KM Tumor response-CT or MRI RECIST Toxicity-NCI CTC version 2.0 | 400 mg/d (473) 800 mg/d (473) | 5% 6% | 45% 48% | 32% 32% | 13% 9% | 5% 5% | 1 yr survival: 400 mg/d = 85% 800 mg/d = 85% 2 yr survival: 400 mg/d = 69% 800 mg/d = 74% 2 yr PFS: 400 mg/d = 44% 800 mg/d = 50% (p =0.026) 220 of the 473 patients on 400 mg/d have PD and 143 have crossed to 800 mg/d; 26% progression free at 1 year with med TTP 78d compared to 203d prior to crossover; toxicity required dose reduction in 31%; interpretation is that crossover is feasible
Casali, 2004^51^ (abstract) | Unk dose [9 mo] | 135 65 [unk] 70% M (129 patients evaluable) | GIST = CD 117 positive All advanced, unresectable or metastatic | Tumor response-RECIST | 129 | | 44% (PR + CR) | | | | PFS > 70%
Phase III
Blay, 2004^52^ (abstract) | Unk doses One year of imatinib then randomized between continuous imatinib vs. interruption of imatinib until progression then restart [6 mo] | 159 Age unk 61% M | Advanced GIST expressing a KIT or PDGFRa mutation | Progression free survival Tumor response | 159 Randomized to continuous N = 23 Randomized to intermittent N = 23 | 10% | 42% | 36% 0% 21% | 6% | 6% | Reintroduction of imatinib yielded tumor control in all 5 who progressed
Rankin, 2004^53^ and Patel 2003^54^ (abstracts) | Randomized between Imatinib 400 mg/d vs Imatinib 800 mg/d (given as 400 mg twice daily) [median 768d, range 70-1029d] | 746 Age unk Gender unk | Metastatic GIST | Progression free survival Overall survival-KM Tumor response | 400 mg | | | | | | 2 yr survival: 400 mg/d = 78% (CI 73–82%) 800 mg/d = 73% (CI 68–77%) 2 yr PFS: 400 mg/d = 50% (CI 45–55%) 800 mg/d = 53% (CI 47–58%) 164 patients at 400 mg/d have progressed and 88/164 crossed over to 800 mg/d, with 7% PR and 29% SD after crossover; after crossover, median PPS = 4 mo and median OS = 19 mo

Abbreviations: CR = complete response; PR = partial response; SD = stable disease; PD = progressive disease; NE = not evaluable; RECIST and CR/PR/SD/PD – see Table 2; NCI = National Cancer Institute; CTC = Common Toxicity Criteria; K-M = Kaplan-Meier; QOL = Quality of life; PM = performance measure; ECOG = Eastern Oncology Cooperative Group performance status scale; OS = overall survival; EFS = event-free survival, see Table 2; STS = soft-tissue sarcoma; NR = not reported; DFS = Disease free survival, see Table 2; Unk = unknown; PFS = progression-free survival, see Table 2; CI = 95% confidence interval

Table 5 Summary of efficacy of imatinib plus surgery for GIST

Study ID | Imatinib dose [length of follow up | No. of patients, age 66, sex | Gist tumor characteristics | Outcomes sought | N | %CR | %PR | %SD | %PD | %NE | Other
Phase II
Bumming, 2003^55^ | 400 mg/d [mean = 10.7 mo] | 17 57 [10–74] 88% M | All patients were high risk or overtly malignant GIST (metastatic disease at presentation) # of prior surgeries 0 = 1 pt 1–3 = 14 pts > 4 = 2 pts non-surgical therapy not stated | Tu response: CT RECIST or PET | Neoadjuvant 1 adjuvant 5 palliative 11 | 100% (5pts) | 100% (1 pt) 73% (8 pts) | 9% (1 pt) | 18% (2 pts)
Retrospective reviews
Rutkowski, 2003^56^ | 400–800 mg/d [median followup 7 mos for patients receiving imatinib and 23 mo overall] | 35 55 [36–79] 69%M | Patients with C-KIT+ GIST that had liver metastases as documented in the database; all patients underwent surgery 57% complete resection 17% microscopically incomplete resection 26% open biopsy only | Tu response: CT RECIST | Surgery 3 imatinib 32 | | 50% | 37.5% | 12.5%
Scaife, 2003^57^ | 76% 400 mg imatinib 6% 600 mg Imatinib 18% 800 mg imatinib [median follow up from imatinib treatment to resection = 10mo; median follow up after surgery = 6mos] | 17 56 [35–76] 59% M | Unresectable intraabdominal c-KIT+ GISTS by CD117 immunohistochemisty. patients who received imatinib pre-operatively (neo-adjuvantly) and then underwent surgical exploration for tumor resection | Tu response: Radiographic change on CT (criteria unclear), PET, or perioperative pathological specimens; Feasibility of surgical resection after treatment with imatinib | CT: 17 PET: 17 pathology: 17 | 6% 55% 12% 94% (complete resection) | 70% 27% 65% | 18% 2% 18% | 6% 0% 6%
Wu, 2003^58^ | 400–800 mg/d [median followup 18 mo with range 4–81] | 57 61 [42–83] 51%M | Diagnosed with GIST and receiving a related surgical resection | OS: Kaplan-Meier Tu response: criteria unclear | all patients who underwent surgery, regardless of use of imatinib patients who underwent surgery and were exposed to imatinib in the adjuvant (for high risk disease; N = 3) or palliative (metastatic disease at resection or relapse; N = 26) settings | 57 29 | 82% complete resections Not clearly stated | 85% with initial PR or SD

### Quality of Life (QOL) on Imatinib with GIST

None of the studies reviewed reported formal QOL analyses. Only Demetri et al. reported any outcomes that could be categorized as QOL.46 This study looked at the effect of imatinib on Eastern Cooperative Oncology Group (ECOG) performance status (Table 6), comparing scores between baseline and 4 months. Some authors consider performance status to be a crude measurement of QOL.67 At baseline 42 percent of participants were ECOG 0 and 19 percent were ECOG 2–3. This substantially improved after imatinib, such that at 4 months 64 percent of participants were ECOG 0 and 5 percent were ECOG 2–3.

Table 6 The Eastern Cooperative Oncology Group (ECOG) performance status scale

0 = fully active
1 = restricted in strenuous activity only
2 = unable to work; up and about more than 50% of waking hours
3 = confined to bed or chair more than 50% of waking hours
4 = completely disabled; totally confined to bed or chair

## Adverse Effects/Harms

Adverse effects that are possibly or likely associated with imatinib for GIST are described in Table 7. The most common adverse effects are edema, nausea, and diarrhea. The edema is predominantly superficial, with some authors breaking this out to highlight the periorbital edema commonly described with imatinib. Few patients (≤ 36 percent) experienced any grade 3 or 4 toxicity at lower doses, and when they did this was predominantly hematological or hemorrhage (≤ 8 percent). These studies were often conducted in patients with bulky, advanced GIST, making it difficult to ascertain which adverse events were truly due to imatinib and which might have occurred due to the disease process itself. Toxicity was somewhat more common at the higher doses, with 800 mg/d being the most toxic dose fully described. These toxicities compare favorably to those of traditional cytotoxic agents.28, 31, 32

Table 7 Percentages of patients reporting adverse events on imatinib dose and grade (gd). The first three pages of this table reflect the adverse events reported in the first three studies and the next 3 pages reflect the second three studies

| Demetri et al. | | | | | | Dagher (representation of Demetri et al. 2002 data) All adverse events reported in this study were those that occurred in ≥ 10% of patients regardless of suspected relationship to treatment | | | | Verweij et al. 2003
Grade | Any grade % | | | Grade 3 or 4 % | | | Any grade % | | Grade 3 or 4 % | | any grade% | Grade 3 or 4 %
Drug | Imatinib | | | | | | Imatinib | | | | Imatinib
Dosage | 400 mg | 600mg | all pts | 400 mg | 600 mg | all pts | 400 mg | 600 mg | 400 mg | 600 mg | 400 mg | 400 mg
Any adverse event with suspected relation to study drug | 97 | 99 | 98 | 21 | 22 | 21
Edema or fluid retention | 71 | 77 | 74 | 1 | 1 | 1 | 71 | 76 | 6 | 3 | 84 | 0
superficial edema | | | | | | | 71 | 76 | 4 | 0
Pleural effussion or ascites | | | | | | | 6 | 4 | 1 | 3
periorbital | 45 | 50 | 48 | 0 | 0 | 0
Leg | 26 | 15 | 20 | 0 | 0 | 0
Face | 8 | 12 | 10 | 1 | 0 | 1
Other site | 7 | 14 | 10 | 0 | 0 | 0
Eyelid | 7 | 8 | 8 | 0 | 0 | 0
Hemorrhage | 11 | 14 | 12 | 4 | 5 | 5 | 18 | 19 | 5 | 8 | 53 | 4
Tumor haemorrhage | 1 | 4 | 3 | 1 | 4 | 3 | 1 | 4 | 1 | 4 | 43 | 4
Cerebral haemorrhage | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0
Upper GI tract | 4 | 3 | 3 | 4 | 1 | 3 | 6 | 4 | 4 | 1 | 37 | 6
Hematologic
Anemia | 6 | 12 | 9 | 1 | 3 | 2
Neutropenia/granulocytopenia | 8 | 5 | 7 | 7 | 3 | 5
Leukopenia | 6 | 4 | 5 | 3 | 0 | 1
Thrombocytopenia | | | | | | | | | | | 55 | 14
Digestive
Diarrhea | 40 | 50 | 45 | 1 | 3 | 2 | 56 | 60 | 1 | 4
Flatulence | 19 | 24 | 22 | 0 | 0 | 0 | 16 | 23 | 0 | 0
Vomiting | 14 | 12 | 13 | 0 | 1 | 1 | 22 | 23 | 1 | 3
Abdominal pain | 26 | 26 | 26 | 1 | 0 | 1 | 37 | 37 | 7 | 3
Vomiting | 14 | 12 | 13 | 0 | 1 | 1 | 22 | 23 | 1 | 3
Dyspepsia | 10 | 12 | 11 | 0 | 0 | 0
Loose stools | 7 | 10 | 8 | 0 | 0 | 0
Constipation
Taste disturbance | 3 | 14 | 8 | 0 | 0 | 0 | 1 | 14 | 0 | 0
Abdominal distension | 6 | 5 | 5 | 0 | 0 | 0
Esophageal reflux | 1 | 7 | 4 | 0 | 0 | 0
Nasopharyngitis | | | | | | | 12 | 14 | 0 | 0
Skin
Pruritus | 3 | 5 | 4 | 0 | 0 | 0
Photosensitivity | 0 | 5 | 3 | 0 | 0 | 0 | | | | | 33 | 6
Dermatitis or rash | 25 | 37 | 31 | 3 | 3 | 3 | 26 | 38 | 3 | 3 | 80 | 12
Whole body
Fatigue | 30 | 39 | 35 | 0 | 0 | 0 | 33 | 38 | 1 | 0
Headache | 19 | 32 | 26 | 0 | 0 | 0 | 25 | 35 | 0 | 0 | 41 | 4
Arthralgia | 1 | 7 | 4 | 0 | 0 | 0
Pain | 6 | 1 | 3 | 0 | 0 | 0 | 11 | 10 | 1 | 0
Blurred vision | 6 | 1 | 3 | 0 | 0 | 0 | | | | | 20
Pyrexia | | | | | | | 12 | 5 | 0 | 0
Insomnia | | | | | | | | 11 | 0 | 0 | 64 | 12
Chills
Increased lacrimation | 7 | 12 | 10 | 0 | 0 | 0 | 6 | 11 | 0 | 0
Anorexia
Dizziness
Cough
Dyspnea
Muscle cramps | | | | | | | 30 | 41 | 0 | 0
Myalgia or musculoskeletal pain | 37 | 42 | 40 | 0 | 0 | 0 | 19 | 11 | 3 | 0
Infection
Neutropenic fever
Upper respiratory tract infection | | | | | | | 6 | 11 | 0 | 0
Neurologic
Paresthesia | 1 | 7 | 4 | 0 | 0 | 0
Metabolic
Renal or genitourinary
Abnormal liver-function results | 6 | 5 | 5 | 3 | 3 | 3

| Verweij et al. 2004 | | | | van Oosterom et al. 2001 most relevant side effects (gd 2 and 3) during first 8 wks | | | | van Oosterom et al. 2002 Update on 2001 paper with data at 8 months
Grade | gd1– gd2 % | gd3– gd4 % | gd1– gd2 % | gd3– gd4 % | % of patients who experience relevant side effect | | | | gd1– gd2 % | gd3– gd4 %
Drug | Imatinib | | Imatinib | | Imatinib | | | | Imatinib
Dosage | 400 mg | | 800 mg | | 400 mg N=8 | 600 mg N=8 | 800 mg N=16 | 1000 mg N=8 | Across dose ranges (400–1000 mg)
Any adverse event with suspected relation to study drug | 67 | 36 | 49 | 51
Edema or fluid retention | 23 | 14 | 78 | 9 | 0 | 25 | 31 | 38 | | 10
Superficial edema
Pleural effussion or ascites | | | | | | | | | | 3
Periorbital | | | | | | | | | 40 (not graded)
Leg | | | | | | | | | | 38
Face
Other site
Eyelid
Hemorrhage | 8 | 0 | 15 | 8
Tumor hemorrhage
Cerebral hemorrhage
Upper GI tract
Hematologic
Anemia | 55 27 | 10 1 | 81 | 17 | | | | | | 12
Neutropenia/granulocytopenia | 20 13 | 0.04 3 | 36 | 7 | | | | | | 17
Leukopenia | 27 13 | 0.03 0 | 45 | 2 | | | | | | 10
Thrombocytopenia | 4 0 | 0 0 | 5 | 0 | | | | | 3
Digestive
Diarrhea | 46 | 1 | 17 | 1 | | | | | 15
Flatulence
Vvomiting | 23 | 0 | 36 | 3 | 25 | 0 | 6 | 25 | | 25
Abdominal pain
Vomiting | 23 | 0 | 36 | 3 | 25 | 0 | 6 | 25 | | 25
Dyspepsia
Loose stools
Constipation | 11 4 | 0.01 0 | 17 | 1
Taste disturbance
Abdominal distension | | | | 2
Esophageal reflux
Nasopharyngitis
Skin
Pruritus | 12 4 | 0 0 | 15 8 | 1 0
Photosensitivity
Dermatitis or rash | 24 | 0 | 42 | 6 | 0 | 13 | 25 | 25 | | 30
Whole body
Fatigue | 62 | 1 | 69 | 12 | | | | | | 30
Headache | 16 | 0 | 13 | 1
Arthralgia | 11 2 | 0 0 | 15 | 1
Pain
Blurred vision
Pyrexia | 8 3 | 0.01 0 | 13 3 | 1 0
Insomnia
Chills
Increased lacrimation
Anorexia | 16 8 | 0.02 0 | 25 13 | 8 0 | | | | | 15
Dizziness | 9 1 | 0 0 | 11 2 | 0.004 0
Cough | 11 2 | 0 0 | 11 3 | 1 0
Dyspnea | 0 8 | 0.03 0 | 0 13 | 3 1 | 0 | 0 | 0 | 13
Muscle cramps
Myalgia or musculoskeletal pain | 25 | 0 | 26 | 0
Infection
Infection | 7 7 | 0.03 0 | 9 8 | 4 0
Neutropenic fever | | | | | 0 | 0 | 6 | 0
Upper respiratory tract infection
Neurologic
Paresthesia
Metabolic
Renal or genitourinary | 9 3 | 0 0 | 48 5 | 2 0.6
Abnormal liver-function results

## Predictors of Response

All reports on predictors of response or survival from the clinical studies of imatinib for GIST are shown in Tables 8–10. Response predictors were divided into three groups: (1) tumor characteristics, (2) radiological studies predicting GIST response to imatinib, and (3) other clinical prognostic factors. Three factors had data from two studies evaluating each factor (c-kit and PDGFRA mutational status, positive emission tomography (PET) as a complementary tool to computed tomography (CT), and performance status). All other factors evaluated were presented in one study only.

The most relevant predictors of response relate to the mechanism of action of imatinib (Table 8). Patients with GIST (presumably expressing CD117) were more likely to respond to imatinib than patients with other soft tissue sarcomas (presumably CD117 negative).48 Patients with identified c-kit mutations were less likely to progress on imatinib and had longer overall survival.59 Both exon 11 and exon 9 mutations positively influenced response to imatinib.47, 59 Some other genetic predictors such as SPRY4 and MAFbx may be clinically relevant, but current studies are too small to make valid conclusions at this time.60

Early response on PET scan at day 8 predicted clinical response to imatinib (Table 9).61 Patients with positive evidence of response on day 8 PET had a 92 percent PFS rate, while those with no evidence of response had a 12 percent PFS rate. Studies of the differential performance of PET vs. CT were mixed, one suggesting PET was a more sensitive indicator of the presence of tumor and the other suggesting no difference between the two modalities. In the high quality study comparing multiple types of PET and CT, combined PET-CT was the most sensitive.62, 63 This study was specifically evaluating the differential ability of the modalities to predict response to imatinib.62 Promising new radiological techniques are on the horizon, some of which may be more sensitive than CT (e.g., angio-echography with BR-1 contrast) and some of which may be as good as CT but less invasive (e.g., ultrasound with perfusion software).64, 65

Other clinical factors associated with poor response to imatinib included poor performance status, lower doses of imatinib, renal dysfunction, and prior chemotherapy (Table 10).47, 49

Table 8 Tumor characteristics predictive of disease response or survival

Characteristic | Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
c-kit mutation | c-kit mutation present vs. absent | Debiec-Rychter et al., 2004 (quality = 6/6)59 | TTP: patients with C kit mutations less likely to progress (p = 0.03) | patients with c-kit mutations with longer OS (p = 0.015)
| Exon 11 mutation | Debiec-Rychter et al., 2004 (quality = 6/6)59 Heinrich et al., 2003 (quality = 6/6)47 | EFS: c-kit exon 11 mutation with median EFS 849d; all other mutations EFS 327d HR 0.17 (0.10–0.29) p < 0.0001^*^ | HR 0.04 (0.01–0.12) p < 0.0001^*^
| Exon 9 mutation | Heinrich et al., 2003 (quality = 6/6)47 | | HR 0.31 (0.11–0.89) p = 0.0289^*^
Other genes | Gene SPRY4 (found to be downregulated by imatinib in in vitro pre-clinical studies) | Frolov et al., 2003 (quality = 1/6)60 | SPRY4 was "dramatically" decreased in 4/5 patients with PR, expressed at high levels in the 2/2 non-responders, and initially decreased then returned to high levels in the 1/5 PR patient who had an early relapse
| Gene MAFbx (found to be upregulated by imatinib in in vitro pre-clinical studies) | Frolov et al., 2003 (quality = 1/6)60 | Variable responses (2/5 PR patients had included levels of MAFbx; initially increased and then returned to pre-treatment levels in the patient with PR but early relapse; not changed at all in the one PD patient)
Pathology | GIST vs. other STS | Verweij et al., 2003 (quality = 6/6)48 | GIST with 73% DFS at 1yr Median TTP STS = 58d

Abbreviations: TTP = time to progression; OS = overall survival; EFS = event free survival; HR = hazard ratio; STS = soft tissue sarcomas; DFS = disease-free survival

* In this study hazard rations greater than one are predictive of poorer prognosis

Table 9 Radiological predictors of disease response or survival

Characteristic | Factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
PET | Evidence of response on Day 8 PET | Stroobants et al., 2003 (quality = 4/6)61 | 1 year PFS: Positive evidence of response on PET at 8 days PFS = 92%, No response to PET at 8 days PFS = 12%, p = 0.00107
PET vs CT (RECIST) | Differential ability to predict response to imatinib (by month of assessment) | Antoch et al., 2004 (quality = 5/5)62 | PET 1 mo 85% 3 mo 100% 6 mo 100% CT 1mo 44% 3 mo 60% 6 mo 57% Combined PET/CT 1mo 95% 3 mo 100% 6 mo 100% Side-by-side PET and CT 1mo 90% 3 mo 100% 6 mo 100%
| Performance of F-FDG PET and CT in staging GISTS | Gayed et al., 2004 (quality = 1/5)63 | Sensitivity: CT 93% PET 86% p = 0.27 Positive predictive value: CT 100% PET 98% p = 0.25
Angio-echography with BR-1 contrast vs. CT (RECIST) | Ability to predict clinical outcome and therapeutic effect of imatinib | De Giorgi et al., 2004 (abstract)64 | Documented tumor response: CT = 46% Angio-echography = 82%
Ultrasound with perfusion software and contrast injection vs. CT | Ability to predict clinical outcome and therapeutic effect of imatinib | Lassau et al., 2004 (abstract)65 | No significant difference between CT and ultrasound’s ability to document response

Abbreviations: PET = FDG positive emission tomography; CT = computed tomography; TTP = time to progression; OS = overall survival; EFS = event free survival; HR = hazard ratio; RECIST = RECIST response criteria – see Table 2; NS = not significant

Table 10 Other clinical predictors of disease response or survival

Characteristic | Prognostic Factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
Performance status | Poor vs. good performance status at baseline | Heinrich et al., 2003 (quality = 6/6)47 Verweij et al., 2004 (quality = 6/6)49 | HR: 1.57 (1.18–2.1) p = 0.0022^*^ No significant relationship | HR: 2.8 (1.57–5.02) p = 0.0005^*^
Dose of imatinib | 600 mg vs. 400 mg dose | Heinrich et al., 2003 (quality = 6/6)47 | HR: 0.57 (0.36–0.91) p = 0.018^*^
Creatinine | Elevated creatinine at baseline vs. not elevated | Heinrich et al., 2003 (quality = 6/6)47 | | HR: 2.9 (0.86–9.80) p = 0.0866^*^
Prior chemotherapy | Prior chemotherapy vs. no prior chemotherapy | Heinrich et al., 2003 (quality = 6/6)47 | | HR: 2.6 (0.98–7.06) p = 0.0558^*^

Abbreviations: PET = FDG positive emission tomography; CT = computed tomography; TTP = time to progression; OS = overall survival; EFS = event free survival; HR = hazard ratio; RECIST = RECIST response criteria – see Table 2; NS = not significant

* In this study hazard rations greater than one are predictive of poorer prognosis