# Methods

## Search Strategy

The search strategy was constructed by combining three concepts: 1) the intervention imatinib; 2) the disease gastrointestinal stromal tumor; and 3) prospective clinical trials. To identify the intervention concept, since these new drugs lack a specific term in the MeSH lexicon, we used text word searching for the following text strings: imatinib or gleevec or glivec or STI571. The disease concept was implemented using the text word searching for gist or adjacent text strings for gastro$ within two words of stromal adjacent to (tumo$ or cancer$). This is designed to detect various spellings such as gastrointestinal stromal tumor or gastrointestinal stromal cancer or gastro-intestinal stromal cancer, etc. A published strategy, validated for finding randomized controlled trials (RCTs), was used to identify prospective clinical trials. This strategy is designed to find all prospective clinical trials (maximize sensitivity), rather than to eliminate non-randomized trials (maximize specificity), and so is appropriate for this study’s goal of finding phase II and III prospective clinical trials. Finally, the three concepts were combined (Boolean “or”). The strategy was executed in MEDLINE (1966 through September 2004, updated February 2005) and limited to articles published in the English language. The exact text of the OVID MEDLINE versions of the search strategy is provided in Appendix A.

Supplemental searches were conducted in International Pharmaceutical Abstracts, The Cochrane Library (Central Register of Controlled Trials (CENTRAL) and Health Technology Assessment 22 database), American Society of Hematology 2004 annual meeting abstracts database, and in the American Society of Clinical Oncology 2004 annual meeting abstracts database. References lists of identified studies and relevant systematic reviews and meta-analyses were hand-checked. Additional articles not indexed in the major bibliographies by September 2004 were identified through ongoing searches and discussions with field experts and monitoring new sources.

## Selection Criteria

Each citation identified from the search strategies was evaluated according to the following selection criteria. Evaluations were performed by the authors.

Inclusion criteria were as follows:

Patients | Patients with unresectable or metastatic GIST
Interventions | Imatinib (Gleevac™ or Glivec™ or (STI571))
Comparators | Any

Study designs:

- For efficacy questions: Prospective clinical trials; may be phase II uncontrolled, or phase III randomized controlled trials.
- For studies of adverse effects: May be retrospective or prospective case series, cohort studies, or clinical trials, provided the number of patients treated (at risk for adverse effects) as well as the number with adverse effects can be ascertained.
- For studies of predictors of response: May be retrospective or prospective case series, cohort studies, case-control studies, or clinical trials, provided the response can be ascertained for patients with and without the predictor.

Outcomes:

- For efficacy questions: Survival, disease-free survival, tumor response, and quality of life (QOL). Tumor response was defined according to Table 2.
- For studies of adverse effects: Adverse effects, tolerability, and compliance with treatment.
- For studies of predictors of response: Predictive value of patient or tumor characteristics that are associated with clinically important differences in treatment response that are:
  1. related to the mechanism of action of the drug (i.e., molecular target); and
  2. candidates for diagnostic testing (even if not commercially or clinically available currently (e.g., Polymerase Chain Reaction)).

Table 2 Definitions of tumor response terminology relevant to GIST^†^

Complete response (CR) | The disappearance of all signs of cancer in response to treatment. This does not always mean the cancer has been cured
Partial response (PR) | A decrease in the size of a tumor, or in the extent of cancer in the body, in response to treatment
Response rate (RR) | The percentage of patients whose cancer shrinks or disappears after treatment. RR = CR + PR
Stable disease (SD) | Cancer that is neither decreasing nor increasing in extent or severity
Progressive disease (PD) | Cancer that is growing, spreading, or getting worse
RECIST criteria | RECIST criteria are a voluntary, international standard for measuring tumor response based on measurable disease (i.e., the presence of at least one measurable lesion). RECIST criteria offer a simplified, conservative, extraction of imaging data and presume that linear measures are an adequate substitute for 2-D methods. There are four response categories: CR = disappearance of all target lesions PR = 30% decrease in the sum of the longest diameter of target lesions PD = 20% increase in the sum of the longest diameter of target lesions SD = small changes that do not meet above criteria
SWOG criteria^‡^ | SWOG criteria are based entirely on CT or MRI CR = disappearance of all disease that could be measured and evaluated PR = ≥ 50 percent decrease in the sum of the products of the perpendicular diameters of all measurable lesions, the absence of progression, and the absence of new lesions PD = ≥ 50 percent increase or an increase of 10 cm^2^ (whichever was smaller) in the sum of the products of the perpendicular diameters of all measurable lesions, worsening of a lesion that could be evaluated, the reappearance of and lesion or the presence of a new lesion SD = a response that did not qualify as a complete response, a partial response or disease progression
Overall survival | The percentage of subjects in a study who have survived for a defined period of time. Usually reported as time since diagnosis or treatment. Also called the survival rate
Time to progression | A measure of time after a disease is diagnosed (or treated) until the disease starts to get worse
Progression-free survival | One type of measurement that can be used in a clinical study or trial to help determine whether a new treatment is effective. It refers to the probability that a patient will remain alive, without the disease getting worse
Disease-free survival | Length of time after treatment during which no cancer is found. Can be reported for an individual patient or for a study population
Event-free survival^*^ | Length of time after treatment that a participant in a clinical study remains free of pre-defined events. Events are defined by the study and can include adverse treatment effects, tumor recurrence/progression, or survival
Survival rate | The percentage of people in a study or treatment group who are alive for a given period of time after diagnosis. This is commonly expressed as 5-year survival

† Except as noted, these definitions were quoted from the NCI’s www.cancer.gov Web site.

* Definition derived from http://www.intelihealth.com/IH/ihtPrint/WSIHW000/8096/8241/347567.html?d=dmtContent&hide=t&k=basePrint#efsurvival.

‡ Defintion from 44

## Data Abstraction

The following data were abstracted from included studies: study design, population characteristics (including sex, age, and diagnosis), eligibility and exclusion criteria, interventions (dose and duration), outcomes assessed and results for each outcome.

We developed data collection forms in Excel (Microsoft; Redmond, WA) and summarized the data in evidence tables formatted like those in a 2003 report from NICE.16

## Quality Assessment

We assessed the quality of included studies by evaluating elements of internal validity (e.g., randomization and allocation concealment; similarity of compared groups at baseline; specification of eligibility criteria; blinding of assessors, care providers, and patients) and external validity (e.g., description of the patient population, similarity to the target population of the report, use of highly selective criteria).

We used as a framework the quality assessment criteria from NICE.16 These are displayed in Appendix B. They provide specific criteria for the range of study designs used in this report including experimental studies, cohort studies, case-control studies, and case series.

Point scores were allocated by assigning one point for each quality category. There were a total of 6 possible categories. Quality ratings of “yes” to a quality criteria were assigned 1 point; no and unknown were both assigned 0 points. The last category, adequate description of subseries, was not applicable to all studies. Hence, the total possible quality points were 5 or 6 depending upon the applicability of the subseries category. High quality studies were those with ≥ 3/5 or 4/6 points.

Abstract quality was not scored.

## Data Synthesis

In addition to the data abstraction and quality analysis, a narrative description of study findings was prepared. Further quantitative analyses were considered, but the available data were not adequate to support these.