# MEDLINE Search Strategy

Database: Ovid MEDLINE(R) <1966 to September Week 3 2004>

Search Strategy

1 | (gefitinib or erlotinib or iressa or tarceva or lapatinib or ekb-569 or ci-1033 or zd1839 or osi-774).mp. (817)
2 | exp lung neoplasms/ or carcinoma, non-small-cell lung/ (96461)
3 | 1 and 2 (339)
4 | randomized controlled trial.pt. (194192)
5 | controlled clinical trial.pt. (67292)
6 | Randomized Controlled Trials/ (34359)
7 | Random Allocation/ (51911)
8 | Double-Blind Method/ (79820)
9 | Single-Blind Method/ (8433)
10 | or/4–9 (329367)
11 | Animal/ not Human/ (2838957)
12 | 10 not 11 (311915)
13 | clinical trial.pt. (392148)
14 | exp Clinical Trials/ (159166)
15 | (clinic$ adj25 trial$).tw. (103424)
16 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (76365)
17 | Placebos/ (23320)
18 | placebo$.tw. (86217)
19 | random$.tw. (294378)
20 | Research Design/ (38965)
21 | (latin adj square).tw. (2126)
22 | or/13–21 (693867)
23 | 22 not 11 (643785)
24 | 23 not 12 (342333)
25 | Comparative Study/ (1152523)
26 | exp Evaluation Studies/ (499768)
27 | Follow-Up Studies/ (288858)
28 | Prospective Studies/ (178265)
29 | (control$ or prospectiv$ or volunteer$).tw. (1483791)
30 | Cross-Over Studies/ (15073)
31 | or/25–30 (2964552)
32 | 31 not 11 (2271429)
33 | 32 not (12 or 24) (1817997)
34 | 12 or 24 or 33 (2472245)
35 | 3 and 34 (241)
36 | limit 35 to english language (216)
37 | from 36 keep 1–216 (216)
38 | (imatinib or gleevec or glivec or STI571).mp. (1613)
39 | exp leukemia, myeloid, chronic/ (9737)
40 | 38 and 39 (718)
41 | 40 and 34 (286)
42 | limit 41 to english language (250)
43 | from 42 keep 1–250 (250)
44 | (gist or (gastro$ adj2 stromal adj (tumo$ or cancer$))).mp. (1111)
45 | 38 and 44 (236)
46 | 45 and 34 (98)
47 | limit 46 to english language (88)
48 | from 47 keep 1–88 (88)