# Excluded Articles

1 Bono P, Krause A, von Mehren M, et al. Serum KIT and KIT ligand levels in patients with gastrointestinal stromal tumors treated with imatinib. Blood. 2004;103(8):2929-2935. [pmid: 15070666].
2 Cho H, Tsuburaya A, Kobayashi O, et al. A risk estimation with tumor size, serosal invasion and MIB-1 labeling index for gastrointestinal stromal tumor (GIST) of the stomach. Journal of Clinical Oncology, 2004 ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22. (14S (July 15 Supplement)):9025 2004.
3 Connolly EM, Gaffney E, Reynolds JV. Gastrointestinal stromal tumours. [Review]. British Journal of Surgery. 2003;90(10):1178-1186. [pmid: 14515284].
4 Croom KF, Perry CM. Imatinib mesylate: in the treatment of gastrointestinal stromal tumours. [Review]. Drugs. 2003;63(5):513-514. [pmid: 12600228].
5 Hensley ML, Ford JM. Imatinib treatment: specific issues related to safety, fertility, and pregnancy. [Review]. Seminars in Hematology. 2003;40(2 Suppl 2):21-25. [pmid: 12783371].
6 Katz D, Segal A, Alberton Y, et al. Neoadjuvant imatinib for unresectable gastrointestinal stromal tumor. Anti-Cancer Drugs. 2004;15(6):599-602. [pmid: 15205603].
7 National Horizon Scanning Centre. Imatinib for gastro-intestinal stromal tumours. Birmingham, UK. National Horizon Scanning Centre (NHSC). 2002. New and Emerging Technology Briefing.
8 National Institute for Clinical Excellence. Imatinib for gastro-intestinal stromal tumours - appraisal (project). London. National Institute for Clinical Excellence (NICE). 2004.
9 Ricci R, Maggiano N, Castri F, et al. Role of PTEN in gastrointestinal stromal tumor progression. Archives of Pathology & Laboratory Medicine. 2004;128(4):421-425. [pmid: 15043466].
10 Wassmann B, Pfeifer H, Scheuring UJ, et al. Early prediction of response in patients with relapsed or refractory Philadelphia chromosome-positive acute lymphoblastic leukemia (Ph^+^ ALL) treated with imatinib. Blood. 2004;103(4):1495-1498. [pmid: 14576058].
11 Wilson JS, Connock M, Song FJ, et al. Imatinib mesylate for the treatment of patients with unresectable and/or metastatic gastrointestinal stromal tumours (GIST). Birmingham. West Midlands Health Technology Assessment Collaboration, University of Birmingham. October. 2003.
1 Bono P, Krause A, von Mehren M, et al. Serum KIT and KIT ligand levels in patients with gastrointestinal stromal tumors treated with imatinib. Blood. 2004;103(8):2929-2935. [pmid: 15070666].
2 Cho H, Tsuburaya A, Kobayashi O, et al. A risk estimation with tumor size, serosal invasion and MIB-1 labeling index for gastrointestinal stromal tumor (GIST) of the stomach. Journal of Clinical Oncology, 2004 ASCO Annual Meeting Proceedings (Post-Meeting Edition). 2004;22. (14S (July 15 Supplement)):9025 2004.
3 Connolly EM, Gaffney E, Reynolds JV. Gastrointestinal stromal tumours. [Review]. British Journal of Surgery. 2003;90(10):1178-1186. [pmid: 14515284].
4 Croom KF, Perry CM. Imatinib mesylate: in the treatment of gastrointestinal stromal tumours. [Review]. Drugs. 2003;63(5):513-514. [pmid: 12600228].
5 Hensley ML, Ford JM. Imatinib treatment: specific issues related to safety, fertility, and pregnancy. [Review]. Seminars in Hematology. 2003;40(2 Suppl 2):21-25. [pmid: 12783371].
6 Katz D, Segal A, Alberton Y, et al. Neoadjuvant imatinib for unresectable gastrointestinal stromal tumor. Anti-Cancer Drugs. 2004;15(6):599-602. [pmid: 15205603].
7 National Horizon Scanning Centre. Imatinib for gastro-intestinal stromal tumours. Birmingham, UK. National Horizon Scanning Centre (NHSC). 2002. New and Emerging Technology Briefing.
8 Ricci R, Maggiano N, Castri F, et al. Role of PTEN in gastrointestinal stromal tumor progression. Archives of Pathology & Laboratory Medicine. 2004;128(4):421-425. [pmid: 15043466].
9 Wassmann B, Pfeifer H, Scheuring UJ, et al. Early prediction of response in patients with relapsed or refractory Philadelphia chromosome-positive acute lymphoblastic leukemia (Ph+ ALL) treated with imatinib. Blood. 2004;103(4):1495-1498. [pmid: 14576058].
10 Wilson JS, Connock M, Song FJ, et al. Imatinib mesylate for the treatment of patients with unresectable and/or metastatic gastrointestinal stromal tumours (GIST). Birmingham. West Midlands Health Technology Assessment Collaboration, University of Birmingham. October. 2003.