# References

1 Connolly EM, Gaffney E, Reynolds JV. Gastrointestinal stromal tumours. British Journal of Surgery. Oct. 2003;90(10):1178-1186. [pmid: 14515284].
2 DeMatteo RP, Lewis JJ, Leung D, et al. Two hundred gastrointestinal stromal tumors: recurrence patterns and prognostic factors for survival. Annals of Surgery. Jan. 2000;231(1):51-58. [pmid: 10636102].
3 Demetri GD, DeMatteo RP. NCCN Gastrointestinal Stromal Tumors (GIST) Task Force Report: National Comprehensive Cancer Network. 2004.
4 Blanke CD, Eisenberg BL, Heinrich MC. Gastrointestinal stromal tumors. Current Treatment Options in Oncology. Dec. 2001;2(6):485-491. [pmid: 12057094].
5 Conlon KC, Casper ES, Brennan MF. Primary gastrointestinal sarcomas: analysis of prognostic variables. Annals of Surgical Oncology. Jan. 1995;2(1):26-31. [pmid: 7834450].
6 van Oosterom AT, Judson I, Verweij J, et al. Safety and efficacy of imatinib (STI571) in metastatic gastrointestinal stromal tumours: a phase I study.[see comment]. Lancet. Oct. 27. 2001;358(9291):1421-1423. [pmid: 11705489].
7 Langer C, Gunawan B, Schuler P, et al. Prognostic factors influencing surgical management and outcome of gastrointestinal stromal tumours. British Journal of Surgery. Mar. 2003;90(3):332-339. [pmid: 12594669].
8 Lin SC, Huang MJ, Zeng CY, et al. Clinical manifestations and prognostic factors in patients with gastrointestinal stromal tumors. World Journal of Gastroenterology. Dec. 2003;9(12):2809-2812. [pmid: 14669339].
9 Graadt van Roggen JF, van Velthuysen ML, Hogendoorn PC. The histopathological differential diagnosis of gastrointestinal stromal tumours. Journal of Clinical Pathology. Feb. 2001;54(2):96-102. [pmid: 11215292].
10 Miettinen M, Sarlomo-Rikala M, Lasota J. Gastrointestinal stromal tumors: recent advances in understanding of their biology. Human Pathology. Oct. 1999;30(10):1213-1220. [pmid: 10534170].
11 Sarlomo-Rikala M, Kovatich AJ, Barusevicius A, Miettinen M. CD117: a sensitive marker for gastrointestinal stromal tumors that is more specific than CD34. Modern Pathology. Aug. 1998;11(8):728-734. [pmid: 9720500].
12 Taniguchi M, Nishida T, Hirota S, et al. Effect of c-kit mutation on prognosis of gastrointestinal stromal tumors. Cancer Research. Sep. 1. 1999;59(17):4297-4300. [pmid: 10485475].
13 Lee JH, Zhang X, Jung WY, et al. DNA ploidy and c-Kit mutation in gastrointestinal stromal tumors. World Journal of Gastroenterology. Dec. 1. 2004;10(23):3475-3479. [pmid: 15526368].
14 Yamaguchi M, Tate G, Endo Y, et al. Immunohistochemistry and c-kit gene analysis in determining malignancy in gastrointestinal stromal tumors. Hepato-Gastroenterology Sep-Oct. 2003;50(53):1431-1435.
15 Miettinen M, Sobin LH, Lasota J. Gastrointestinal stromal tumors of the stomach: a clinicopathologic, immunohistochemical, and molecular genetic study of 1765 cases with long-term follow-up. American Journal of Surgical Pathology. Jan. 2005;29(1):52-68. [pmid: 15613856].
16 Wilson J, Connock M, Song F, et al. Imatinib for the treatment of patients with unresectable and/or metastatic gastro-intestinal stromal tumours -- a systematic review and economic evaluation. Birmingham, UK. National Institute for Clinical Excellence. October. 10. 2003. 2003.
17 Ernst SI, Hubbs AE, Przygodzki RM, et al. KIT mutation portends poor prognosis in gastrointestinal stromal/smooth muscle tumors. Laboratory Investigation. Dec. 1998;78(12):1633-1636. [pmid: 9881963].
18 Yasuoka R, Sakakura C, Shimomura K, et al. Mutations in exon 11 of the c-kit gene in a myogenic tumor and a neurogenic tumor as well as in gastrointestinal stromal tumors. Utility of c-kit mutation as a prognostic biomarker for gastrointestinal mesenchymal tumor. Digestive Surgery. 2003;20(3):183-191. [pmid: 12759497].
19 Morey AL, Wanigesekera GD, Hawkins NJ, et al. C-kit mutations in gastrointestinal stromal tumours. Pathology. Aug. 2002;34(4):315-319. [pmid: 12190287].
20 Antonescu CR, Sommer G, Sarran L, et al. Association of KIT exon 9 mutations with nongastric primary site and aggressive behavior: KIT mutation analysis and clinical correlates of 120 gastrointestinal stromal tumors. Clinical Cancer Research. Aug. 15. 2003;9(9):3329-3337. [pmid: 12960119].
21 Lasota J, Kopczynski J, Sarlomo-Rikala M, et al. KIT 1530ins6 mutation defines a subset of predominantly malignant gastrointestinal stromal tumors of intestinal origin. Human Pathology. Dec. 2003;34(12):1306-1312. [pmid: 14691917].
22 Yamamoto H, Oda Y, Kawaguchi K, et al. c-kit and PDGFRA mutations in extragastrointestinal stromal tumor (gastrointestinal stromal tumor of the soft tissue). American Journal of Surgical Pathology. Apr. 2004;28(4):479-488. [pmid: 15087667].
23 Hirota S, Ohashi A, Nishida T, et al. Gain-of-function mutations of platelet-derived growth factor receptor alpha gene in gastrointestinal stromal tumors. Gastroenterology. Sep. 2003;125(3):660-667. [pmid: 12949711].
24 Miettinen M, El-Rifai W, Sobin LH, et al. Evaluation of malignancy and prognosis of gastrointestinal stromal tumors: a review. Human Pathology. May. 2002;33(5):478-483. [pmid: 12094372].
25 Fletcher CDM, Berman JJ, Corless C, et al. Diagnosis of gastrointestinal stromal tumors: a consensus approach. Human Pathology. 2002;33(5):459-465. [pmid: 12094370].
26 Tryggvason G, Gíslason HG, Magnússon MK, et al. Gastrointestinal stromal tumors in Iceland, 1990–2003: the Icelandic GIST study, a population-based incidence and pathologic risk stratification study`. International Journal of Cancer. 2005;117:289-293.
27 Heinrich MC, Shoemaker JS, Corless CL, et al. Correlation of target kinase genotype with clinical activity of imatinib mesylate (IM) in patients with metastatic GI stromal tumors (GISTs) expressing KIT (KIT+). 2005 ASCO Annual Meetings. 2005. Abstract #7.
28 Anonymous. Adjuvant chemotherapy for localised resectable soft-tissue sarcoma of adults: meta-analysis of individual data. Sarcoma Meta-analysis Collaboration. Lancet. Dec. 6. 1997;350(9092):1647-1654. [pmid: 9400508].
29 Frustaci S, De Paoli A, Bidoli E, et al. Ifosfamide in the adjuvant therapy of soft tissue sarcomas. Oncology. Suppl 2. 2003;65:80-84. [pmid: 14586155].
30 Adult Soft Tissue Sarcoma (PDQ®): Treatment: Recurrent Adult Soft Tissue Sarcoma. 2/1/05; http://cancer.gov/cancertopics/pdq/treatment/adult-soft-tissuesarcoma/HealthProfessional/page8#Reference8.12. Accessed March 27, 2005.
31 Demetri GD, Elias AD. Results of single-agent and combination chemotherapy for advanced soft tissue sarcomas. Implications for decision making in the clinic. Hematology - Oncology Clinics of North America. Aug. 1995;9(4):765-785.
32 Bramwell V, Anderson D, Charette M. Doxorubicin-based chemotherapy for the palliative treatment of adult patients with locally advanced or metastatic soft tissue sarcoma Practice Guideline Report #11-1. July. 2004. http://www.cancercare.on.ca/pdf/pebc11-1f.pdf. Accessed March 27, 2005.
33 Biermann JS, Baker LH. The future of sarcoma treatment. Seminars in Oncology. Oct. 1997;24(5):592-597. [pmid: 9344326].
34 Antman KH, Ryan L, Elias A, et al. Response to ifosfamide and mesna: 124 previously treated patients with metastatic or unresectable sarcoma. Journal of Clinical Oncology. Jan. 1989;7(1):126-131. [pmid: 2491883].
35 van Oosterom AT, Mouridsen HT, Nielsen OS, et al. Results of randomised studies of the EORTC Soft Tissue and Bone Sarcoma Group (STBSG) with two different ifosfamide regimens in first- and second-line chemotherapy in advanced soft tissue sarcoma patients. European Journal of Cancer. Dec. 2002;38(18):2397-2406. [pmid: 12460784].
36 Patel SR, Vadhan-Raj S, Papadopolous N, et al. High-dose ifosfamide in bone and soft tissue sarcomas: results of phase II and pilot studies―dose-response and schedule dependence. Journal of Clinical Oncology. Jun. 1997;15(6):2378-2384. [pmid: 9196153].
37 Antman K, Crowley J, Balcerzak SP, et al. An intergroup phase III randomized study of doxorubicin and dacarbazine with or without ifosfamide and mesna in advanced soft tissue and bone sarcomas. Journal of Clinical Oncology. Jul. 1993;11(7):1276-1285. [pmid: 8315425].
38 Blanke CD, Corless CL. State-of-the Art Therapy for Gastrointestinal Stromal Tumors. Cancer Investigation. 2005;23(3):278-280.
39 von Mehren MWJC. Gastrointestinal stromal tumors. Hematology Oncology Clinics of North America. 2005;19(3):547-564. vii.
40 Eisenberg BL. Imatinib mesylate: a molecularly targeted therapy for gastrointestinal stromal tumors. Oncology (Huntington) 1626 passim. Nov. 2003;17(11):1615-1620. 1623; discussion 1620.
41 Corless CL, Schroeder A, Griffith D, et al. PDGFRA mutations in gastrointestinal stromal tumors: frequency, spectrum and in vitro sensitivity to imatinib. Journal of Clinical Oncology. 2005;23(23):5357-5364. [pmid: 15928335].
42 Gleevec® and GIST. 2005. http://www.gleevec.com/info/page/gist. Accessed March 27, 2005.
43 Dagher R, Cohen M, Williams G, et al. Approval summary: imatinib mesylate in the treatment of metastatic and/or unresectable malignant gastrointestinal stromal tumors. Clinical Cancer Research. Oct. 2002;8(10):3034-3038. [pmid: 12374669].
44 Demetri GD, von Mehren M, Blanke CD, et al. Efficacy and safety of imatinib mesylate in advanced gastrointestinal stromal tumors. New England Journal of Medicine. 2002;347(7):472-480. [pmid: 12181401].
45 van Oosterom AT, Judson IR, Verweij J, et al. Update of phase I study of imatinib (STI571) in advanced soft tissue sarcomas and gastrointestinal stromal tumors: a report of the EORTC Soft Tissue and Bone Sarcoma Group. European Journal of Cancer. Sep. Suppl 5. 2002;38:S83-S87. [pmid: 12528778].
46 Demetri GD, von Mehren M, Blanke CD, et al. Efficacy and safety of imatinib mesylate in advanced gastrointestinal stromal tumors.[see comment]. New England Journal of Medicine. Aug. 15. 2002;347(7):472-480. [pmid: 12181401].
47 Heinrich MC, Corless CL, Demetri GD, et al. Kinase mutations and imatinib response in patients with metastatic gastrointestinal stromal tumor. Journal of Clinical Oncology. Dec. 1. 2003;21(23):4342-4349. [pmid: 14645423].
48 Verweij J, van Oosterom A, Blay JY, et al. Imatinib mesylate (STI-571 Glivec, Gleevec) is an active agent for gastrointestinal stromal tumours, but does not yield responses in other soft-tissue sarcomas that are unselected for a molecular target. Results from an EORTC Soft Tissue and Bone Sarcoma Group phase II study.[see comment]. European Journal of Cancer. Sep. 2003;39(14):2006-2011. [pmid: 12957454].
49 Verweij J, Casali PG, Zalcberg J, et al. Progression-free survival in gastrointestinal stromal tumours with high-dose imatinib: randomised trial.[see comment]. Lancet. Sep. 25. 2004;364(9440):1127-1134. [pmid: 15451219].
50 Zalcberg J, Verweij J, Casali PG, et al. Outcome of patients with advanced gastrointestinal stromal tumors (GIST) crossing over to a daily imatinib dose of 800mg (HD) after progression on 400mg (LD)―an international, intergroup study of the EORTC, ISG and AGITG. Journal of Clinical Oncology. 2004;22(14S):9004.
51 Casali P, Fumagalli E, Messina A, et al. Tumor response to imatinib mesylate in advanced GIST. Journal of Clinical Oncology. 2004;22(14S):9028.
52 Blay J-Y, Berthaud P, Perol D, et al. Continuous vs intermittent imatinib treatment in advanced GIST after one year: a prospective randomized phase III trial of the French Sarcoma Group. Journal of Clinical Oncology. 2004;22(14S):9006.
53 Rankin C, von Mehren M, Blanke C, et al. Dose effect of imatinib (IM) in patients (pts) with metastatic GIST - Phase III Sarcoma Group Study S0033. Journal of Clinical Oncology. 2004;22(14S):9005.
54 Patel SR. Early results from randomized phase III trial of imatinib mesylate for gastrointestinal stromal tumors. Current Oncology Reports. Jul. 2003;5(4):273. [pmid: 12781067].
55 Bumming P, Andersson J, Meis-Kindblom JM, et al. Neoadjuvant, adjuvant and palliative treatment of gastrointestinal stromal tumours (GIST) with imatinib: a centre-based study of 17 patients. British Journal of Cancer. Aug. 4. 2003;89(3):460-464. [pmid: 12888812].
56 Rutkowski P, Nyckowski P, Grzesiakowska U, et al. The clinical characteristics and the role of surgery and imatinib treatment in patients with liver metastases from c-Kit positive gastrointestinal stromal tumors (GIST). Neoplasma. 2003;50(6):438-442. [pmid: 14689066].
57 Scaife CL, Hunt KK, Patel SR, et al. Is there a role for surgery in patients with"unresectable" cKIT+ gastrointestinal stromal tumors treated with imatinib mesylate?. American Journal of Surgery. Dec. 2003;186(6):665-669. [pmid: 14672776].
58 Wu PC, Langerman A, Ryan CW, et al. Surgical treatment of gastrointestinal stromal tumors in the imatinib (STI-571) era. Surgery. Oct. 2003;134(4):656-665. discussion 665-656. [pmid: 14605627].
59 Debiec-Rychter M, Dumez H, Judson I, et al. Use of c-KIT/PDGFRA mutational analysis to predict the clinical response to imatinib in patients with advanced gastrointestinal stromal tumours entered on phase I and II studies of the EORTC Soft Tissue and Bone Sarcoma Group. European Journal of Cancer. Mar. 2004;40(5):689-695. [pmid: 15010069].
60 Frolov A, Chahwan S, Ochs M, et al. Response markers and the molecular mechanisms of action of Gleevec in gastrointestinal stromal tumors. Molecular Cancer Therapeutics. Aug. 2003;2(8):699-709. [pmid: 12939459].
61 Stroobants S, Goeminne J, Seegers M, et al. 18FDG-Positron emission tomography for the early prediction of response in advanced soft tissue sarcoma treated with imatinib mesylate (Glivec).[see comment]. European Journal of Cancer. Sep. 2003;39(14):2012-2020. [pmid: 12957455].
62 Antoch G, Kanja J, Bauer S, et al. Comparison of PET, CT, and dual-modality PET/CT imaging for monitoring of imatinib (STI571) therapy in patients with gastrointestinal stromal tumors. Journal of Nuclear Medicine. Mar. 2004;45(3):357-365. [pmid: 15001674].
63 Gayed I, Vu T, Iyer R, et al. The role of 18F-FDG PET in staging and early prediction of response to therapy of recurrent gastrointestinal stromal tumors.[erratum appears in J Nucl Med 2004 Nov;45(11):1803]. Journal of Nuclear Medicine. Jan. 2004;45(1):17-21. [pmid: 14734662].
64 De Giorgi U, Aliberti G, Benea G, et al. Effect of angio-echography with a second-generation contrast agent to assess tumor response to imatinib treatment in patients with advanced gastrointestinal stromal tumor (GIST): Comparison with computerized tomography (CT). Journal of Clinical Oncology. 2004;22(14S):4216.
65 Lassau N, Lamuraglia M, Leclere J, et al. Doppler-Ultrasonography with perfusion software and contrast medium injection as an early evaluation tool of gastro intestinal stromal tumor (GIST) treated by imatinib: Results of a prospective study. Journal of Clinical Oncology. 2004;22(14S):9048.
66 Hellies R, Sulis R, Puliga A, et al. [GIST: surgical treatment of 34 cases]. Tumori. Jul-Aug. 2003;89(4 Suppl):133-134. [pmid: 12903571].
67 Michael M, Tannock IF. Measuring health-related quality of life in clinical trials that evaluate the role of chemotherapy in cancer treatment. Canadian Medical Association Journal. 1998;158(13):1727-1734. [pmid: 9676550].
68 Dematteo RD, Heinrich MC, El-Rifai WM, et al. Clinical management of gastrointestinal stromal tumors: before and after STI-571. Human Pathology. 2002;33(5):466-477. [pmid: 12094371].
69 Demetri G, von Mehren M, Joensuu H, et al. Lack of progress is the most significant measure of patients's lack of clinical benefit: correlating the effects of imatinib meslyate therapy in gastrointestinal stromal tumor (GIST) with survival benefits. Annals of Oncology. 2004;15(s3):iii202.
70 ClinPharm Online. http://cpipgsmcom/. 2005.
71 Verweij J, Casali PB, Zalcberg J, et al. Progression-free survival in gastrointestinal stromal tumours with high-dose imatinib: randomised trial. Lancet. 2004;364:1127-1134. [pmid: 15451219].
72 Zalcberg JR, Verweij J, Casali PG, et al. Outcome of patients with advanced gastrointestinal stromal tumors (GIST) crossing over to a daily imatinib dose of 800mg (HD) after progression on 400mg (LD) - an international, intergroup study of the EORTC, ISG and AGITG. Journal of Clinical Oncology. 2004;22(14):9004.
73 Rankin C, Von Mehren M, Blanke C, et al. Dose effect of imatinib (IM) in patients (pts) with metastatic GIST - Phase III Sarcoma Group Study S0033. Journal of Clinical Oncology. 2004;22(14):9005.
74 D'Amato G, Steinert DM, McAuliffe JC, et al. Update on the biology and therapy of gastrointestinal stromal tumors. Cancer Control. 2005;12(1):44-56. [pmid: 15668652].
75 Milandri C, Passardi A, Dall'agata M, et al. Gastrointestinal stromal tumors and breast cancer: any correlation? Report of two clinical cases. Journal of Clinical Oncology. 2005;23(16S). abstract #9049.
76 Linton KM, Taylor MB, Radford JA. Response evaluation in GIST treated with imatinib-misdiagnosis of disease progression on CT due to cystic change in liver metastases. Journal of Clinical Oncology. 2005;23(16S). abstract # 9047.
77 Khan A. Efficacy of imatinib mesylate in metastatic GIST to the brain. Journal of Clinical Oncology. 2005;23(16S). abstract #9050.
78 Leong KW, Goh SA. Observation study on Asian patients taking Imatinib mesylate in comparison to published data focusing on dosage and adverse events. Journal of Clinical Oncology. 2005;23(16S). abstract #6727.
79 Gronchi A, Fiore M, Bertulli R, et al. Surgery of residual disease following Imatinib mesylate in advanced gastrointestinal stromal tumors (GIST). Journal of Clinical Oncology. 2005;23(16S). abstract # 9038.
80 Rutkowski P, Nowecki Z, Nyckowski P, et al. Surgical treatment of patients (pts) with gastrointestinal stromal tumors (GIST) after imatinib mesylate (IM) therapy. Journal of Clinical Oncology. 2005;23(16S). abstract 9037.
81 Trent JC, Choi H, Hunt K, et al. Apoptotic and anti-vascular activity of imatinib in GIST patients. Journal of Clinical Oncology. 2005;23(16S). abstract # 9001.
82 Lassau N, Lamuraglia M, Chami L, et al. Doppler-Ultrasonography with perfusion software and contrast medium injection as a tool for early evaluation of gastro-intestinal 50 stromal tumors (GIST) treated with Imatinib. Journal of Clinical Oncology. 2005;23(16S). abstract #3057.
83 Blackstein Me, Rankin CJ, Fletcher C, et al. Clinical benefit of Imatinib in patients (pts) with metastatic Gastrointestinal Stromal Tumors (GIST) negative for the expression of CD117 in the S0033 trial. Journal of Clinical Oncology. 2005;23(16S). abstract#9010.
84 Dileo P, Rankin CJ, Bejamin RS, et al. Incidence and reasons for dose modification of standard-dose vs. high-dose Imatinib Mesylate (IM) in the Phase III Intergroup Study S0033 of patients (pts) with unresectable or metastatic Gastrointestinal Stromal Tumor (GIST). Journal of Clinical Oncology. 2005;23(16S). abstract#9032.
85 Heinrich M, Shoemaker JS, Corless CL, et al. Correlation of target kinase genotype with clinical activity of imatinib mesylate (IM) in patients with metastatic GI stromal tumors (GISTs) expressing KIT (KIT+). Journal of Clinical Oncology. 2005;23(16S). abstract#7.
86 Ray-Coquard I, Perol D, Bui BN, et al. Prognostic factors for progression free and overall survival in advanced GIST: results from the BFR14 phase III trial of the French Sarcoma Group. Journal of Clinical Oncology. 2005;23(16S). abstract # 9035.
87 Le Cesne A, Perol D, Ray-Coquard I, et al. Interruption of imatinib (IM) in GIST patients with advanced disease: updated results of the prospective French Sarcoma Group randomized phase III trial on survival and quality of life. Journal of Clinical Oncology. 2005;23(16S). abstract # 9031.
88 Dematteo RP, Antonescu CR, Chadaram V, et al. Adjuvant imatinib mesylate in patients with primary high risk gastrointestinal stromal tumor (GIST) following complete resection: Safety results from the U.S. Intergroup Phase II trial ACOSOG Z9000. Journal of Clinical Oncology. 2005;23(16S). Abstract #9009.
89 Bustamante F, Castillo E, Silva A, et al. Experiences with gastrointestinal stromal tumour at the Oncology Hospital Siglo XXI IMSS. Journal of Clinical Oncology. 2005;23(16S). abstract # 9048.
90 Stepanova E, Meshcheryakov A, Anurova O, et al. Immunohistochemical markers as prognostic indicators for efficacy of imatinib therapy in GIST. Journal of Clinical Oncology. 2005;23(16S). abstract #9703.
91 Ryu M, Lee H, Kim T, et al. p53 mutation as a determinant of prognosis in GIST patients treated with Imatinib mesylate. Journal of Clinical Oncology. 2005;23(16S). abstract # 9018.
92 Kim J, Lim M, Kim I, et al. Prognostic analysis of gastrointestinal stromal tumor by mitotic activity, size of tumor and mutational type of C-Kit protein. Journal of Clinical Oncology. 2005;23(16S). abstract#9046.
93 Aliberti S, Grignani G, Allione P, et al. Erythrocyte macrocytosis is a rather common, apparently uneventful yet unexplained finding in GIST imatinib (I) chronic therapy. Journal of Clinical Oncology. 2005;23(16S). abstract # 9045.
94 Nilsson B, Bümming P, Meis-Kindblom JM, et al. Gastrointestinal stromal tumors The incidence, prevalence, clinical course, and prognostication in the preimatinib mesylate era. A population-based study in Western Sweden. Cancer. 2005;103(4):821-829. [pmid: 15648083].