# Scope of Report

The Centers for Medicare & Medicaid Services (CMS) requested that AHRQ commission an evidence report to inform CMS of the evidence regarding ultrasound-based monitoring of cardiac output (Doppler). Accordingly, on May 9^th^ 2006, AHRQ, in consultation with CMS and ECRI, issued a Statement of Work (SOW) contracting ECRI to prepare an evidence report on this topic. AHRQ, in consultation with CMS and ECRI, developed four Key Questions to be addressed. These questions are as follows:

1. What types of devices/techniques are currently used to assess cardiac output?
2. Does therapeutic management based on esophageal Doppler ultrasound-based cardiac output monitoring during surgery lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to:
  a. Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
  b. Catheter-based measurement of central venous pressure?
  c. Conventional clinical assessment (physical examination, fluid input and output measurements)?
3. Does therapeutic management based on esophageal Doppler ultrasound-based cardiac output monitoring during hospitalization lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to:
  a. Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
  b. Catheter-based measurement of central venous pressure?
  c. Conventional clinical assessment (physical examination, fluid input and output measurements)?
4. What complications, harms, and adverse events associated with esophageal Doppler ultrasound-based monitoring have been reported?

The esophageal Doppler ultrasound devices evaluated in this report include the following: CardioQ, HemoSonic 100, and TECO. Earlier models of these devices (some with different names than the current models) were also included. These devices differ from transesophageal echocardiography (TEE) with Doppler in that they require less training to operate and are less expensive.(1) TEE systems are beyond the scope of this report.

As shown in the Key Questions, this report focuses on patient-oriented outcomes. Validation studies that compared the agreement between Doppler ultrasound cardiac output measurements and measurements obtained with comparable technologies (e.g., thermodilution) were beyond the scope of this report. Such comparisons are generally performed within the same patients, whereas any comparison of clinical outcomes requires that the compared technologies must be used to direct fluid replacement in different patients.