# Methods

## Key Questions Addressed

We address the following Key Questions in this report:

1. What types of devices/techniques are currently used to assess cardiac output?
2. Does therapeutic management based on esophageal Doppler ultrasound cardiac output monitoring during surgery lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to:
  a. Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
  b. Catheter-based measurement of central venous pressure?
  c. Conventional clinical assessment (physical examination, fluid input and output measurements)?
3. Does therapeutic management based on esophageal Doppler ultrasound cardiac output monitoring during hospitalization lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to:
  d Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
  e Catheter-based measurement of central venous pressure?
  f Conventional clinical assessment (physical examination, fluid input and output measurements)?
4. What complications, harms, and adverse events associated with esophageal Doppler ultrasound monitoring have been reported?

In assessing safety, we consider all reported complications that may be related to use of esophageal Doppler ultrasound devices.

Figure 1 illustrates the relationship between esophageal Doppler monitoring, the Key Questions, and the outcomes of interest. Because Key Question 1 is not evidence-based (it merely asks what are the alternative technologies used to measure cardiac output), it is not included in Figure 1. This report evaluates only patient-oriented outcomes, including total complications, major complications (generally defined as life-threatening or requiring intensive or high dependency care), mortality, and length of hospital stay. Intermediate outcomes such as increased cardiac output cannot be perceived by the patient and are beyond the scope of this report. They are presented in Figure 1 only to show their place within the analytic framework.

Figure 1 Analytic Framework

Figure 1. Analytic Framework

## Literature Searches

Details of our literature searches, which included searches of 17 electronic databases, hand searches of the bibliographies of all retrieved articles, and searches of the gray literature, are presented in Appendix A.

## Study Inclusion/Exclusion Criteria

### General Inclusion/Exclusion Criteria

We used the following general criteria to determine which studies would be included in our analysis for Key Questions 1 through 4:

1. Studies must have been published in English. We recognize the possibility that requiring studies to be published in English could lead to bias, but we believe it is sufficiently unlikely that we cannot justify the additional time and expense for translation.(23,24)
2. Studies must have addressed one of the Key Questions.
3. Studies must have been published as full journal articles (no meeting abstracts). Meeting abstracts generally have insufficient description of methods to allow assessment of quality, and the reported results often contain discrepancies with results presented in later peer-reviewed publication of the same study.
4. If the same study is reported in multiple publications, only the most recent publication will be included. This serves to avoid duplication of data.
5. For controlled studies, 10 or more patients per treatment group must have been enrolled. This increases the likelihood that the studies contain a representative sampling of the patient population.

### Question-Specific Inclusion/Exclusion Criteria

The following inclusion/exclusion criterion was specific to Key Question 1:

- Clinical guidelines, review articles, and FDA approvals will be used to identify other methods of cardiac output monitoring

The following inclusion/exclusion criteria were specific to Key Questions 2 and 3:

- Studies must include parallel control groups – controlled studies are required in situations where influences other than the technology of interest may be responsible for treatment outcomes. Comparison of esophageal ultrasound-based monitoring to a standard-of-care-monitored control group (ideally catheter-based measurements of cardiac output or CVP, but also including other conventional clinical assessments) is needed to sort out the influence of the monitoring technology from other potential influences. Trials that compare two monitoring technologies in the same patients cannot be used to determine which technology leads to better clinical outcomes. Therefore, only trials with head-to-head comparisons of esophageal ultrasound and standard-of-care monitoring in separate patients will be examined.
- Within a given trial, patients in both groups must have received comparable surgery (for Key Question 2) or must have had comparable diagnoses (for Key Question 3)
- Studies cannot perform a mixed analysis of surgical and non-surgical patients (such a study would not answer Key Question 2 or 3).

The following inclusion/exclusion criterion was specific to Key Question 4:

- Studies of any design (controlled trials, case series, case reports), ECRI’s Health Device Alerts database and other adverse event databases will be examined for reports of complications, harms and adverse events. These sources cannot be used to determine causality or to estimate frequency of adverse events, but can be used to generate a list of adverse events possibly attributable to the technology.

## Identification of Evidence Bases

The selection process used to identify the articles that comprise the evidence base for the key questions addressed in this report is presented in Figure 2. One relevant study published after the original search cutoff date (June 2006) was brought to our attention by external reviewers. Accordingly, we performed an updated search (September 2006) to identify any additional relevant studies that may have been published since the initial search. Together, our searches identified 317 articles that potentially addressed Key Questions 1 through 4. Of these 317 articles, we retrieved 75. Key Question 1 did not involve an evaluation of evidence, but instead was a survey of current techniques used for cardiac output monitoring. As such, we do not include it as part of the selection process in Figure 2. Seven included articles addressed Key Question 2, one included study addressed Key Question 3, and 23 included articles addressed Key Question 4 (Four of these 23 also also addressed Key Question 2). The included studies are listed in the Evidence Synthesis section under each Key Question that they address.

Figure 2 Summary of Study Selection Process

* 3 articles addressed Key Questions 2 and 4

Figure 2. Summary of Study Selection Process. 317 citations identified for screening. 242 rejected at abstract level. 75 articles retrieved. 48 excluded:. 19 – Studies used TEE probes, not esophageal Doppler probes. 29 – Studies did not report information about complications or any relevant outcome. 27 articles included*. 6 for Key Question 2. 1 for Key Question 3. 23 for Key Question 4. * 3 articles addressed Key Questions 2 and 4

## Data Extraction

Information extracted from the included studies is presented in Evidence Tables in Appendices C–F. These tables describe patient inclusion/exclusion criteria, design details (prospective, blinding status, etc.), information on enrolled patients (demographics, underlying risk, etc.), and study results. When study authors did not report dichotomous data as percentages, we computed percentages. We have only extracted outcome data relevant to the Key Questions in this report.

## Evaluation of the Quality of the Evidence Base

ECRI’s algorithm, which is presented in Appendix B, provides systematic, reproducible, transparent, and a priori decision rules for rating the strength of a body of evidence. In applying the algorithm, we draw a distinction between a qualitative conclusion (one which answers the question “Does it work?”) and a quantitative conclusion (one which answers the question “How well does it work?”). Second, we utilize an algorithm that we developed to assign a strength rating to the evidence that supports our qualitative conclusions and a rating that defines how stable we believe any estimate of treatment effect to be.

Table 2 presents definitions of the strength of evidence and stability ratings that may be obtained using the algorithm. These definitions, which are similar to those proposed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group,(25) are intuitive. Qualitative conclusions that are supported by strong evidence are less likely to be overturned by the publication of new data than are conclusions supported by weak evidence. Likewise, quantitative estimates of treatment effect that are backed up by stable data (data with relatively narrow confidence intervals) are less likely to change significantly when new data are published than are estimates of treatment effect drawn from a less stable data set. For more information on the criteria used to rate studies, see the Quality of Included Studies section under each Key Question in the Evidence Synthesis section of the report.

Table 2 Interpretation of Strength of Evidence and Stability Ratings

Strength of Evidence Interpretation
Qualitative Conclusion (Does it work?)
Strong evidence | Evidence supporting the qualitative conclusion is convincing. It is highly unlikely that new evidence will lead to a change in this conclusion.
Moderate evidence | Evidence supporting the qualitative conclusion is somewhat convincing. There is a small chance that new evidence will overturn or strengthen our conclusion. ECRI recommends regular monitoring of the relevant literature at this time.
Weak evidence | Although some evidence exists to support the qualitative conclusion, this evidence is tentative and perishable. There is a reasonable chance that new evidence will overturn or strengthen our conclusions. ECRI recommends frequent monitoring of the relevant literature at this time.
Inconclusive | Although some evidence exists, this evidence is not of sufficient strength to warrant drawing an evidence-based conclusion from it. ECRI recommends frequent monitoring of the relevant literature at this time.
Quantitative Conclusion (How well does it work?)
High stability | The estimate of treatment effect included in the conclusion is stable. It is highly unlikely that the magnitude of this estimate will change substantially as a result of the publication of new evidence.
Moderate stability | The estimate of treatment effect included in the conclusion is somewhat stable. There is a small chance that the magnitude of this estimate will change substantially as a result of the publication of new evidence. ECRI recommends regular monitoring of the relevant literature at this time.
Low stability | The estimate of treatment effect included in the conclusion is likely to be unstable. There is a reasonable chance that the magnitude of this estimate will change substantially as a result of the publication of new evidence. ECRI recommends frequent monitoring of the relevant literature at this time.
Unstable | Estimates of the treatment effect are too unstable to allow a quantitative conclusion to be drawn at this time. ECRI recommends frequent monitoring of the relevant literature.

We apply each kind of rating to the body of evidence that addresses each outcome, not to individual studies. We also rate on an outcome-by-outcome basis. Four primary factors determine our ratings for both strength and stability; the quality, quantity, robustness, and consistency of the evidence. Under certain circumstances, the size of the treatment’s effect, and whether mega-trials (trials with ≥ 1000 patients) are available also influence our ratings of the evidence underlying qualitative conclusions.

We estimated the generalizability of each study to the U.S. Medicare population using study enrollment criteria and the reported characteristics of the patients who were actually enrolled in the study.

## Statistical Methods

We calculated individual study effect sizes from dichotomous data using the log odds ratio (summary log odds ratios were converted to odds ratios in the text and conclusion statements). If there were no events in one of the study groups, the Peto log odds and odds ratios were used, as this method is appropriate for rare events in studies with no substantial imbalance in the number of patients in each comparison group. An alternative method used to calculate effect size (Cohen’s h, the arcsin transform of the difference between proportions) from dichotomous data was described by Snedecor and Cochran.(26) Effect sizes for continuous data (e.g., length of hospital stay) were calculated in the original metric (the weighted mean difference in days).

In some instances, certain studies presented data for a continuous outcome (length of hospital stay) in a form that did not allow calculation of a precise effect size. Whereas accurate calculation of an effect requires means and standard deviations (SDs) or 95% confidence intervals, some studies report length of stay as medians and ranges. Because in some studies the mean length of hospital stay may be markedly skewed by an outlier, the median becomes a superior measure of the average patient experience. For this reason, we used imputation methods to estimate effect sizes from the median, range, and sample size when possible as described by Pudar Hozo et al.(27) If studies reported medians and interquartile ranges (IQRs), we assumed the distance between the median and the 25^th^ percentile was 0.67 SDs. If medians were not available, effect sizes were calculated from means and SDs.

Whenever relevant data from three or more studies were available and could be combined (and assuming that the studies used similar enough clinical methods that combining was considered appropriate), we summarized the results using meta-analysis. Meta-analysis allows one to pool data from different studies to obtain an average estimate of the treatment effect. It also provides a means for formally identifying and exploring important differences among the results of different studies (consistency). For a complete description of when studies can be combined in a meta-analysis, see Appendix B under Strength of Evidence Algorithm.

In brief, we first tested the available data to determine whether the results of the studies included in the meta-analysis differed from one another by more than that expected by chance (heterogeneity testing) using the I^2^ statistic (I^2^≥50% indicates notable unexplained inconsistency).(28) If study results did not differ in this manner (i.e., the data were consistent), we next pooled the study results in a fixed-effects model to obtain a summary estimate.(29) Random effects meta-analysis was performed to enable a qualitative conclusion if I^2^≥50% or if fewer than 80% of studies reported the outcome of interest or had calculable effect sizes.

Having obtained a summary estimate of the results, we then tested the robustness of our findings using sensitivity analyses as recommended by Olkin.(30) This involved the removal of each individual study separately to determine whether any one study had a substantial influence on the meta-analytic findings. We also performed the systematic addition of each study (cumulative meta-analysis) to determine the study’s effect on the summary result. Studies were added in order, beginning with the highest-weighted study and ending with the lowest-weighted study (we also added them in reverse order, from lowest-weighted to highest-weighted). These sensitivity analyses were used for testing both quantitative and qualitative robustness. As a further test of qualitative robustness, we re-calculated summary effects in a different metric (Cohen’s h in place of the log odds ratio, Hedges’ g in place of the weighted mean difference) to see if this overturned the qualitative conclusions. Because of the assumptions used in meta-analysis of length of stay, additional sensitivity analyses were undertaken on this outcome (described under findings for Key Question 2).

In instances where the evidence base consisted of two studies and the median quality of the studies was high, we combined the studies in a meta-analysis in an attempt to reach a qualitative (but not quantitative) conclusion.