# Executive Summary

The Centers for Medicare & Medicaid Services (CMS) requested that AHRQ commission an evidence report to inform CMS of the evidence regarding ultrasound-based monitoring of cardiac output (Doppler). This is currently listed as a Category II procedure (clinical reliability and efficacy not proven), which is “considered experimental and should not be covered at this time”. Accordingly, on May 9^th^ 2006, AHRQ, in consultation with CMS and ECRI, issued a Statement of Work (SOW) contracting ECRI to prepare an evidence report on this topic.

In commissioning this report, AHRQ, in consultation with CMS and ECRI, developed four Key Questions to be addressed. These four Key Questions are presented below.

Key Question 1 What types of devices/techniques are currently used to assess cardiac output?
Key Question 2 Does therapeutic management based on esophageal Doppler ultrasound-based cardiac output monitoring during surgery lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to:
  a. Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
  b. Catheter-based measurement of central venous pressure?
  c. Conventional clinical assessment (physical examination, fluid input and output measurements)?
Key Question 3 Does therapeutic management based on esophageal Doppler ultrasound-based cardiac output monitoring during hospitalization lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to:
  a. Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
  b. Catheter-based measurement of central venous pressure?
  c. Conventional clinical assessment (physical examination, fluid input and output measurements)?
Key Question 4 What complications, harms, and adverse events associated with esophageal Doppler ultrasound-based monitoring have been reported?

## Data Sources

We searched 17 external and internal databases, including PubMed and EMBASE, for clinical trials on the use of esophageal Doppler ultrasound for cardiac output monitoring. In addition, we routinely reviewed more than 1,600 journals and supplements maintained in ECRI’s collections to determine if they contained relevant information. We also examined the bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature includes reports and studies produced by local government agencies, private organizations, educational facilities, and corporations that do not appear in the peer-reviewed journal literature.) Although we examined gray literature sources to identify relevant information, we only consider published, peer-reviewed literature in this report.

## Evidence Bases

Our searches identified 317 potentially relevant articles. Of these, we retrieved 75 full-length articles. We read each article in full to determine whether it met a set of general and question-specific a priori inclusion criteria. Twenty-seven of the retrieved articles met the inclusion criteria for at least one key question. Four of the 27 included articles addressed more than one of our four key questions. Key Question 1 is not evidence-based; instead, it requires a summary of the technologies currently used to measure cardiac output. The information addressing this question is derived primarily from review articles written by experts in the field. The evidence base for Key Question 2 consisted of seven studies, the evidence base for Key Question 3 consisted of one study, and the evidence base for Key Question 4 consisted of 23 studies.

## Main Findings and Conclusions

### Key Question 1 What types of devices/techniques are currently used to assess cardiac output?

Several methods are currently used to monitor cardiac output in patients during surgery or intensive care. These methods include thermodilution, dye dilution, lithium dilution, methods using the Fick principle, pulse contour methods, thoracic electrical bioimpedance, transesophageal echocardiography, esophageal Doppler monitoring, and ultrasonic cardiac output monitoring.

### Key Question 2 Does therapeutic management based on esophageal Doppler ultrasound-based cardiac output monitoring during surgery lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to

a. Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
b. Catheter-based measurement of central venous pressure (CVP)?
c. Conventional clinical assessment (physical examination, fluid input and output measurements)?

After searching the literature, retrieving articles, and applying the inclusion/exclusion criteria, we identified seven publications with 583 patients that addressed this question. None of these studies compared esophageal Doppler monitoring to thermodilution. Five studies compared esophageal Doppler with CVP plus conventional clinical assessment to CVP plus conventional clinical assessment. The median quality of these five studies was high, and the age generalizability to the Medicare population was fair. Two studies compared esophageal Doppler with conventional clinical assessment to conventional clinical assessment alone (one of these studies also compared esophageal Doppler with conventional clinical assessment to CVP with conventional clinical assessment). The median quality of these two studies and their generalizability in terms of patient age to the Medicare population was high.

The addition of esophageal Doppler monitoring for guided fluid replacement to a protocol using CVP and conventional clinical assessment during surgery leads to a clinically significant reduction in the rate of major complications and total complications in surgical patients compared to CVP plus conventional clinical assessment. The strength of evidence supporting this finding is strong. Because only three of five studies separately reported major complications, and because of differences in the way total complications were reported, no quantitative conclusion is presented for these outcomes.

The addition of esophageal Doppler monitoring to the protocol described above also reduces the length of hospital stay for surgical patients (clinical significance uncertain). The strength of evidence supporting this finding is strong. The lack of a calculable precise effect size in some studies precluded a quantitative summary estimate of the reduction in length of stay.

Only one study compared esophageal Doppler plus conventional clinical assessment to CVP plus conventional clinical assessment. Because this was one small study with non-informative effect sizes, no evidence-based conclusions were possible for any of the outcomes of interest.

The addition of esophageal Doppler monitoring for guided fluid replacement to conventional clinical assessment during surgery leads to a clinically significant reduction in the length of hospital stay compared to that associated with conventional clinical assessment alone. The strength of evidence supporting this finding is weak. The low number of studies (two) precluded a quantitative estimate of the reduction in length of hospital stay. Because only a single study reported total complications, no conclusion was possible concerning this outcome.

The evidence was insufficient to allow conclusions to be reached concerning relative mortality rates for any of the comparisons in Key Question 2.

The conclusions for Key Question 2 only apply to patients undergoing surgical procedures with an expected substantial blood loss or fluid shifts requiring fluid replacement.

### Key Question 3 Does therapeutic management based on esophageal Doppler ultrasound-based cardiac output monitoring during hospitalization lead to improved patient outcomes (fewer complications and shorter hospital stay), compared to

a. Pulmonary artery catheter-based measurement of cardiac output via thermodilution?
b. Catheter-based measurement of central venous pressure?
c. Conventional clinical assessment (physical examination, fluid input and output measurements)?

After searching the literature, retrieving articles, and applying the inclusion/exclusion criteria, we identified one study that compared esophageal Doppler monitoring plus CVP plus conventional clinical assessment to CVP plus conventional clinical assessment for optimization of intravenous fluid replacement in patients admitted to intensive care following cardiac surgery. This study was judged to be of high quality based on ECRI ratings. Generalizability to the Medicare population was fair. However, this was a single small study without a demonstrably large treatment effect on the outcomes of interest. Therefore, no conclusions could be reached for this question.

### Key Question 4 What complications, harms, and adverse events associated with esophageal Doppler ultrasound-based monitoring have been reported?

Currently, no serious adverse events associated with esophageal Doppler probes have been reported in the literature or in adverse event databases. The only minor events identified included two cases of incorrect probe placement in the left main bronchus, one case of incorrect placement in the trachea, a tube displacement during probe removal, and an unspecified number of cases of minimal trauma in the buccal cavity during probe placement. Nineteen studies with a total of 654 patients specifically stated that esophageal Doppler probes did not cause any complications. The number of patients represented in these studies is relatively small. However, the available evidence suggests that esophageal Doppler probes are relatively low-risk devices, as reporting of even minor morbidity has been infrequent thus far.