# Evidence Synthesis

## Key Question 1 What Types of Devices/Techniques Are Currently Used to Assess Cardiac Output?

This question requires a summary of the technologies currently used to measure cardiac output. The information described in this section is derived primarily from review articles written by experts in the field, and is not truly evidence-based.

### Summary of Technologies Used to Measure Cardiac Output

A variety of invasive and non-invasive methods are currently used to measure cardiac output. The ideal technique would be easy to apply, operator independent, without morbidity, accurate, reproducible, continuous use, and cost-effective. None of the available techniques meets all of these criteria.(31) Each method and its advantages and limitations are described below.

#### Thermodilution (via a Pulmonary Artery Catheter)

Thermodilution refers to the measurement of blood flow based on induction of a known change in the intravascular heat content of flowing blood at one point of the circulation, and detection of the resultant change in temperature at a point downstream.(32) Measurement requires insertion of a pulmonary artery catheter (PAC) through the right atrium of the heart with the tip placed in the pulmonary artery. For many years, the standard thermodilution technique involved introduction of a fluid bolus (colder than the patient’s blood) through the proximal port of the PAC into the right atrium. The injected fluid mixes with blood passing through the tricuspid valve into the right ventricle. As the cooler blood passes the catheter tip located in the pulmonary artery, a thermistor within the catheter senses the temperature change. A computer attached to the catheter calculates a curve for change in temperature over time and converts it into a measurement of cardiac output.(33) This method allows intermittent but not continuous cardiac output measurement.(34)

A more recent alternative to bolus thermodilution is continuous thermodilution, so named because it allows continuous measurement of cardiac output. This technique uses a modified PAC containing a thermal filament (maintained in the right ventricle) that continuously transfers heat directly into the blood. As in bolus thermodilution, the temperature change is detected downstream by the thermistor located in the catheter tip, and cardiac output is calculated by a computer. However, in this instance the computer continuously displays cardiac output readings that are updated every 30 seconds to provide an average flow over the previous three to five minutes.(34)

Although often used as the “reference” method when evaluating other methods of cardiac output measurement, thermodilution is not a true “gold standard” technique. Under ideal circumstances, the fluid bolus method has a 10% error rate related to instrument inaccuracies, operator error, and temperature transduction.(33) The relative accuracy of the continuous method is uncertain. Furthermore, the invasiveness of these methods carries a risk of serious complications, which has led some investigators to prefer less invasive methods of cardiac output measurement.

#### Dye Dilution

An indicator dilution method similar to bolus thermodilution is injection of a known concentration of a colored dye (such as indocyanine green) into the pulmonary artery. The concentration of dye after equilibration is measured at a downstream site (usually the femoral or radial artery). The moment-to-moment dye concentration measured spectrophotometrically by a densitometer produces a curve. This allows calculation of cardiac output, which equals 60× the dose of injected dye divided by the area under the curve (average dye concentration × time).(35) Dye dilution appears to be less widely used than thermodilution or lithium dilution (described below).

#### Lithium Dilution

Lithium dilution is used to measure cardiac output using a principle similar to bolus thermodilution and dye dilution. Unlike thermodilution or dye dilution, Lithium chloride (LiCl) can be injected into a central or peripheral vein, which may decrease the risk of serious complications. An arterial catheter with an attached lithium sensor records the arterial lithium concentration time curve; this data are transmitted to a hemodynamic monitor that calculates cardiac output based on the following formula: cardiac output = LiCl dose × 60area × (1−haematocrit) lmin^−1^. LiCl is administered in a bolus of 0.15 to 0.3 mmol (for an average adult) and has no known pharmacological side effects at this dose range. Nevertheless, it is recommended that not more than 10 to 20 boluses should be administered to a single patient.(7) Like bolus thermodilution, this method allows only intermittent, rather than continuous, measurement of cardiac output. However, the commercially available lithium dilution cardiac output (LiDCO^TM^) system (LiDCO Ltd., London, UK) can be used as an indicator method in conjunction with another method that does allow continuous cardiac output measurement (see below under Pulse Contour Cardiac Output).(36)

#### Pulse Contour Cardiac Output

Analysis of the arterial pulse pressure waveform, measured by an arterial catheter, can be used to calculate cardiac output. The pulse pressure waveform results from the interaction between stroke volume and the mechanical characteristics of the arterial tree. Pulse contour methods use the pressure waveform to predict stroke volume. An independent technique is required to provide initial calibration of the continuous cardiac output analysis. The two major commercially available devices use different methods for calibration. PiCCO (PULSION Medical Systems AG, Munich, Germany) uses transpulmonary thermodilution measured from a central venous line (PAC not needed) to a central arterial line (femoral or axillary) for calibration purposes, while PulseCO (LiDCO Ltd., London, U.K.) uses lithium dilution for this purpose.(37)

A more recent modification of pulse contour analysis, known as the pressure recording analytical method (PRAM), can derive cardiac output from the pressure waveform without requiring an independent calibration method.(38) However, this method has not yet been widely evaluated.

#### Methods Using The Fick Principle (Direct Oxygen and Inert Gas Rebreathing)

The Fick principle enables calculation of cardiac output as the ratio between the consumption of any gas diffusing through the lungs (e.g., carbon dioxide) and the difference between arterial and venous blood levels of the gas. Commercially available devices use the Fick principle to measure either oxygen or carbon dioxide (CO_2_). Devices that measure oxygen have the drawback of requiring invasive central venous and arterial catheters for mixed arterial and venous blood samples, and they cannot be used in patients ventilated with a fractional inspired oxygen (FiO2) greater than 60%; thus, they often cannot be used in critically ill patients.(37)

In contrast, devices that use the Fick principle to measure CO_2_ (inert gas rebreathing) allow non-invasive determination of cardiac output. The NICO monitor (Novametrix Medical Systems, Inc., Wallingford, CT) calculates CO_2_ production from minute ventilation and arterial CO_2_ is estimated from end-tidal CO_2_. Partial rebreathing reduces CO_2_ elimination and increases end-tidal CO_2_. Combining measurements under normal and rebreathing conditions allows omission of venous CO_2_ from the Fick equation, eliminating the need for a central venous catheter.(2,37) This method only measures blood flow that participates in gas exchange. However, it does provide an estimate of the amount of blood that bypasses the lungs (the intrapulmonary shunt); this amount added to the amount involved in gas exchange comprises the total cardiac output.(34) This method requires the patient to be under fully controlled mechanical ventilation, and arterial blood samples are required for shunt estimation.(2) Also, poor hemodynamic instability and increased intrapulmonary shunt may decrease the precision of cardiac output estimation with this method.(37)

#### Thoracic Electrical Bioimpedance

Thoracic electrical bioimpedance (TEB, also known as impedance plethysmography) uses four electrodes attached to the neck and thorax to provide continuous assessment of cardiac output. A high frequency, low amplitude electric current is passed across the thorax. The electrodes measure changes in electrical impedance (resistance to flow) of the thoracic cavity as aortic blood flow increases and decreases in response to the beating heart.(39) Changes in impedance correlate with stroke volume and allow calculation of stroke volume (and ultimately, cardiac output). Although this is a completely non-invasive method, the degree of methodological diversity (including different available electrode arrays and equations that produce differing results), difficulties in placing electrodes, questions about accuracy and other methodological issues have limited the diffusion of this technique for cardiac output measurement.(7)

#### Transesophageal Echocardiography

Transesophageal echocardiography (TEE) for measuring cardiac output has some features in common with esophageal Doppler monitoring. Like the latter technique, TEE uses an esophageal probe that can employ Doppler monitoring to calculate blood flow velocity, and an M-mode transducer to measure the cross-sectional area of the aorta (although the M-mode transducer is used in only one commercially available esophageal Doppler probe). Unlike esophageal Doppler, TEE can employ multiplane imaging to more accurately visualize cardiovascular anatomy. Other differences include the higher cost of TEE and the higher level of training required to use TEE.(7) Another limitation of TEE is a small risk of pharyngeal or esophageal perforation.(40) Such events have not yet been recorded for esophageal Doppler probes, possibly because these latter probes are smaller than TEE probes (see Key Question 4 for more information).

#### Esophageal Doppler Monitoring

See background section for description of this technology.

#### Ultrasonic Cardiac Output Monitoring (USCOM)

USCOM is a new system that employs continuous-wave Doppler ultrasound to measure cardiac output.(31) Unlike TEE and esophageal Doppler systems, USCOM does not require insertion of an esophageal probe. Instead, a transducer is placed on the patient’s chest and positioned to measure either transpulmonary or transaortic blood flow. Thus, this method is completely non-invasive. The cross-sectional area of the aorta is estimated by the Nidorf equation or measured directly via another imaging method (e.g., echocardiography).(41) Because this is a relatively new device, it has not been widely evaluated at this time.

### Subsection Summary

Several methods are currently used to monitor cardiac output in patients during surgery or intensive care. These methods include thermodilution, dye dilution, lithium dilution, methods using the Fick principle, pulse contour methods, thoracic electrical bioimpedance, transesophageal echocardiography, esophageal Doppler monitoring, and ultrasonic cardiac output monitoring.

## Key Question 2 Does Therapeutic Management Based on Esophageal Doppler Ultrasound Cardiac Output Monitoring During Surgery Lead to Improved Patient Outcomes (Fewer Complications and Shorter Hospital Stay), Compared to Catheter-Based Measurement of Cardiac Output (Thermodilution) or Central Venous Pressure, or Conventional Clinical Assessment?

### Evidence Base

Our searches found eight randomized controlled trials (RCTs) that potentially addressed this question. On retrieval, one of the eight articles was found not to meet our inclusion criteria for this question. This study addressed Key Question 3 and is evaluated later in this report.

Seven RCTs with a total of 583 patients remained to address Key Question 2. These studies are listed in Table 3. No included studies compared the efficacy of esophageal Doppler monitoring to thermodilution with a pulmonary artery catheter for optimization of intravenous fluid replacement. Five studies with a total of 453 patients compared the efficacy of esophageal Doppler monitoring plus central venous pressure (CVP) monitoring plus conventional clinical assessment to CVP plus conventional clinical assessment to optimize intravenous fluid replacement. These studies were basically asking whether Doppler monitoring is an effective complementary procedure to CVP plus conventional protocol. Two studies with a total of 130 patients compared the efficacy of esophageal Doppler monitoring plus conventional clinical assessment to conventional clinical assessment to optimize intravenous fluid replacement. One of these two studies also compared esophageal Doppler monitoring to CVP as a competing, rather than complementary, procedure. Details of these studies are presented in Tables D-1 to D-3, Appendix D. Although all of the studies except Venn et al. reported placing Doppler probes in the control group patients during surgery, Doppler monitoring was not used in the fluid maintenance protocol in control patients (at a minimum, the anesthesiologist was blinded to the esophageal Doppler readings). Six of the seven studies used either the CardioQ esophageal Doppler monitoring system or an earlier model of this system. The remaining study (Conway et al.) used the TECO esophageal Doppler monitoring system.

Table 3 Evidence Base for Key Question 2

Randomized Controlled Trials | EDM + CVP + conventional clinical assessment vs. CVP + conventional clinical assessment | Noblett et al. 2006(42) Wakeling et al. 2005(43); Conway et al. 2002^a^(44); Gan et al. 2002^a^(11); Mythen and Webb 1995(45)
| EDM + conventional clinical assessment vs. CVP + conventional clinical assessment | Venn et al. 2002(46)
| EDM + conventional clinical assessment vs. Conventional clinical assessment | Venn et al. 2002(46); Sinclair et al. 1997(47)

CVP Central Venous Pressure Assessment

EDM Esophageal Doppler Monitoring

a The studies by Conway et al. and Gan et al. did not use CVP as part of the algorithm for guiding additional fluid challenges in the EDM group. However, CVP was used as part of routine fluid management in most patients in the EDM and control groups.

The types of surgery performed in these studies appear in Table D-1, Appendix D. Three of the studies comparing esophageal Doppler monitoring plus CVP plus conventional clinical assessment to CVP plus conventional clinical assessment included patients undergoing elective bowel surgery. Of the remaining two studies in this group, one included patients undergoing elective general, urologic, or gynecologic surgery, and the other included patients undergoing elective cardiac surgery. Within each study, the type of surgery performed in the Doppler-monitored and control groups was identical. Although the types of surgery differ across studies, they all have one thing in common: an anticipated major loss of blood or significant fluid shifts requiring fluid replacement. This is the key factor that makes esophageal Doppler monitoring applicable to these surgeries. Doppler monitoring is expected to provide similar benefits to these differing types of surgeries because the need for fluid replacement is similar across these procedures. Therefore, it is reasonable to combine data from these studies in a meta-analysis.

Two other studies, both including patients who received surgery for hip fracture repair, were analyzed as a separate group because they performed a different clinical comparison (Doppler monitoring plus conventional clinical assessment vs conventional clinical assessment alone).

### Quality of Included Studies

As shown in Table 4, five studies that compared esophageal Doppler monitoring with CVP monitoring plus conventional clinical assessment to CVP plus conventional clinical assessment had a median quality score of 8.9 on the ECRI quality scale for controlled trials (a study with no flaws would score 10 on our 0–10 scale). Thus, the quality rating for this evidence base is high (for more details on the quality scale, see Appendix B).

Table 4 Quality of Included Studies Addressing Key Question 2

Reference | Year | ECRI Quality Score (Rating)
Trials comparing EDM + CVP + conventional protocol to CVP + conventional protocol
Noblett et al.(42) | 2006 | 9.7 (High)
Wakeling et al.(43) | 2005 | 9.0 (High)
Conway et al.(44) | 2002 | 8.5 (High)
Gan et al.(11) | 2002 | 8.1 (Moderate)
Mythen and Webb(45) | 1995 | 8.9 (High)
Median quality score | | 8.9 (High)
Trials comparing EDM + conventional protocol to CVP + conventional protocol
Venn et al.(46) | 2002 | 9.0 (High)
Trials comparing EDM + conventional protocol to conventional protocol
Venn et al.(46) | 2002 | 9.0 (High)
Sinclair et al.(47) | 1997 | 8.9 (High)
Median quality score | | 9.0 (High)

Two studies comparing esophageal Doppler monitoring plus conventional clinical assessment to conventional clinical assessment had a median quality score of 9.0, so the quality rating for this evidence base is high. One of these studies (Venn et al.) also compared esophageal Doppler monitoring to CVP.

Tables D-4 and D-5 in Appendix D show the individual study scores based on the answers to each question in the ECRI quality scale.

### Details of Study Enrollees and Study Generalizability

Patient enrollment criteria appear in Table D-1, Appendix D, and characteristics of included patients appear in Table D-2, Appendix D. Of the factors determining generalizability to the Medicare population, age is a key factor. For example, in a study where 100% of the patients are age 65 or older, all of these patients belong to some subset of the Medicare population. The same cannot be said of studies which include patients below age 65, regardless of what other clinical characteristics these patients may have. Thus, for each study we rated the age generalizability of enrolled patients based on the percentage of patients in the age range 65 or above.

We note that certain of the exclusion criteria of these studies may be relevant for assessment of generalizability to the Medicare population. Some studies excluded patients with heart failure, renal dysfunction, esophageal disease, or patients requiring emergency surgery. However, many of the criteria listed are criteria of surgical eligibility; these criteria may be applied to anyone otherwise eligible for surgery and are not particularly useful for evaluating generalizability to the Medicare population. For some of these procedures, only a fraction of the Medicare population would be considered surgical candidates or would be likely to undergo the procedure. Determination of generalizability based on surgical eligibility criteria would require knowledge of the percentage and characteristics of Medicare patients who would be candidates and/or likely to undergo a given procedure. Although some exclusion criteria are not related to surgical eligibility and therefore more useful for determining generalizability, it is often difficult to determine which category each individual criterion belongs to. Due to the lack of such information, we did not attempt to determine an overall generalizability rating based on study exclusion criteria.^1^

1 A similar problem arises when considering patient characteristics such as gender. For example, one study of older hip fracture patients is comprised of about 80% women (Venn et al. 2002).(46) Although the overall Medicare population is less than 80% women, this does not mean the study is not generalizable; women are more likely to have osteoporosis and in turn more likely to suffer hip fractures. Thus, one would expect a higher percentage of women in studies of hip fracture surgery. The study is generalizable to the subgroup of Medicare patients most likely to require this procedure.

The five studies that compared esophageal Doppler monitoring plus central venous pressure (CVP) monitoring plus conventional clinical assessment to CVP plus conventional clinical assessment had some overlap with the Medicare population, but the age ranges were generally large, ranging from young adult to elderly. Therefore, the median age generalizability of these studies to the Medicare population is “Fair.”^2^ Table 5 provides the estimated percentage of patients (calculated by ECRI) in each study with age ≥65 years.

2 High = Characteristics of ≥75% of enrolled patients typical of Medicare population; Fair = Characteristics of ≥33% to <75% of enrolled patients typical of Medicare population; Poor = Characteristics of <33% of enrolled patients typical of Medicare population (or enrolled patients represent a subgroup of Medicare population).

Table 5 Age Generalizability of Studies to the Medicare Population

Reference | Year | Percentage of patients age 65 and older | Age generalizability rating
Trials comparing EDM + CVP + conventional protocol to CVP + conventional protocol
Noblett et al.^b^(42) | 2006 | 50% | Fair
Wakeling et al.^a^(43) | 2005 | 70% | Fair
Conway et al.^b^(44) | 2002 | 57% | Fair
Gan et al.^b^(11) | 2002 | 27% | Poor
Mythen and Webb^C^(45) | 1995 | 44% | Fair
Median age generalizability | | 49.5% | Fair
Trials comparing EDM + conventional protocol to CVP + conventional protocol
Venn et al.^d^(46) | 2002 | 100% | High
Trials comparing EDM + conventional protocol to conventional protocol
Venn et al.^d^(46) | 2002 | 100% | High
Sinclair et al.^a^(47) | 1997 | 87% | High
Median age generalizability | | 93.5% | High

a The study reported only the medians and interquartile ranges (IQRs), so to estimate the percentage, ECRI assumed a normal distribution and that the 25^th^ and 75^th^ percentiles were each 0.675 SDs from the mean.

b The study reported only the means and SDs, so ECRI estimated this percentage by assuming a normal distribution of age.

c The study reported only the means and ranges, so to estimate the percentage, ECRI assumed a normal distribution and that the minimum and maximum were each 2.5 SD from the mean.

d The study only included patients who were 65 years or older.

The two studies that compared esophageal Doppler monitoring plus conventional clinical assessment to conventional clinical assessment alone were more age generalizable to the Medicare population. Venn et al. excluded patients with age less than 65 years,(46) while Sinclair et al. excluded patients with age less than 55 years.(47) The average age of patients in these studies was in the mid-seventies (Sinclair et al.) and the mid-eighties (Venn et al.), with. Therefore, the age generalizability of these studies to the Medicare population is “High.”^2^ Table 5 provides more specific information for each study. Females represented the majority of patients (about 80%) in the study by Venn et al. (Sinclair et al. did not report information on patient gender). However, the high percentage of women is not unusual given the advanced age of the patients and the increased risk of hip fractures among women.

Further details of the patients enrolled in these studies are presented in Table D-1 and D-2 in Appendix D.

### Findings of Included Studies

#### Studies Comparing Esophageal Doppler Monitoring Plus CVP Plus Conventional Assessment to CVP Plus Conventional Assessment

Three of the five studies that addressed this question used CVP on a discretionary basis (i.e., some but not all patients received CVP monitoring).(11,44) Since patients that did not receive CVP appeared to be distributed equally in both groups, we considered it acceptable to group these studies with the two studies wherein all patients received CVP monitoring. These same three studies did not employ CVP in the actual algorithm used to guide fluid challenges in the Doppler-monitored group. However, CVP was used as part of the routine management of patients in both the Doppler-monitored and control groups.

A brief discussion concerning analysis of complications is warranted. Ideally, analysis would be performed not only on total complications but also on individual complications. However, because different studies reported complications in different ways, the evidence did not permit analysis of most individual complications. The one exception was death, which was reported separately in each study. In any event, a comparison of individual minor complications (e.g. nausea) does not capture the experience of patients with multiple complications, some of which are more serious than others.

Three of the five studies reported “major” complications (see definition under Major Complications below) separate from total complications, thus allowing a separate analysis of these more severe complications. The specific types of major complications were relatively similar among the relevant studies (for further details, see Table D-6, Appendix D).

Total complications (including major and less severe complications) were reported by four of the five studies. Some complications were more specific to the type of surgery being performed, and other complications (such as infections and pulmonary complications) were reported across studies (see Table D-6, Appendix D). However, many of these complications may be triggered or exacerbated by hypovolemia and tissue hypoxia.(11) Thus, it is reasonable to assume that Doppler-guided fluid replacement would have a similar impact on total complications regardless of the type of surgery performed in these studies. Therefore, a combined analysis of total complications from studies of different surgical procedures is appropriate.

##### Mortality

Five studies with a total of 453 patients reported the number of deaths in each treatment group (see Table D-7, Appendix D). None of these studies reported any deaths occurring during surgery. Three studies reported one death each in the control group within 30 days following surgery, and one study reported a death in the control group within 60 days following surgery. The total number of deaths is too low to allow pooling of data in a meta-analysis, and the effect sizes of the individual studies are non-informative (none of the studies showed a statistically significant between-group difference and the confidence intervals are too large to demonstrate equivalence). Therefore, no conclusion is possible regarding mortality.

##### Major Complications

Three of five studies reported only major complications (Mythen and Webb) or reported these complications separately from lesser complications (Noblett et al., Conway et al.). Major complications were generally defined as life-threatening or requiring intensive or high dependency care (for further details, see Table D-6, Appendix D). Table D-8 in Appendix D presents the individual study results. All studies showed a statistically significant reduction in major complications in the Doppler-monitored group.

Our test for between-study differences revealed no substantial differences among study results (I^2^ = 0%), indicating that the study results could be combined in a meta-analysis. Because each study reported no major complications in the Doppler-monitored groups, we used the Peto method for calculating log odds ratios and odds ratios in our analyses. However, because only three of five available studies presented separate data on major complications, the possibility of selective reporting of positive data remains (although the three studies show highly consistent results). Under such circumstances, the rules of our algorithm prevent a quantitative conclusion.

We then proceeded to pool the studies in a random-effects meta-analysis to arrive at a qualitative conclusion. Pooling these studies resulted in a Peto odds ratio that was statistically significant (p = 0.00002) and showed a reduction in major complications associated with Doppler-monitored fluid replacement (see Table 6 below). The next step involved testing with multiple sensitivity analyses to determine the strength of the qualitative conclusion. The most rigorous sensitivity analysis involved inclusion of the two studies that did not separately report major complications, with the assumption that the major complication rates were equal in the Doppler and control groups in these two studies. None of the sensitivity analyses overturned that qualitative findings, indicating that the summary effect was qualitatively robust (Table D-12, Appendix D). Therefore, the strength of evidence supporting the qualitative conclusion (that Doppler-guided fluid replacement during surgery leads to a clinically significant reduction in major complications compared to the control protocol) is strong. This conclusion applies only to patients undergoing surgical procedures with an expected substantial blood loss or fluid compartment shifts requiring fluid replacement.

Table 6 Meta-analysis – Major Complications (EDM + CVP + Conventional Assessment vs. CVP + Conventional Assessment)

Study | N = | Effect Size | Lower 95% CI | Upper 95% CI | p-value | I^2^ | Forest Plot
| | | | | | | [image]
Noblett et al.(42) | 103 | −2.08 | −3.72 | −0.44 | 0.01 | NA | [image]
Conway et al.(44) | 57 | −2.19 | −4.01 | −0.37 | 0.02 | NA | [image]
Mythen and Webb(45) | 60 | −2.19 | −3.86 | −0.51 | 0.01 | NA | [image]
Random-effects summary Peto log odds ratio | 220 | NC | −3.14 | −1.17 | 0.00002 | 0% | [image]
Random-effects summary Peto odds ratio | 220 | NC | 0.04 | 0.31 | 0.00002 | 0%

NA Not Applicable

NC Not Calculated

##### Total Complications

Four of five studies reported total complications (the remaining study by Mythen and Webb reported only major complications and was excluded from this analysis). Table D-9 in Appendix D presents the individual study results. Two of the four studies showed a statistically significant difference indicating fewer total complications in the Doppler-monitored group (the remaining studies also showed fewer complications in the Doppler group, but the difference was not significant). Three of these studies (Noblett et al., Wakeling et al., Conway et al.) reported the total number of patients with complications in each group, while Gan et al. reported the number of complications rather than number of patients with complications. Our test for between-study differences revealed no substantial differences among study results (I^2^ = 0%), indicating that the study results could be combined in a meta-analysis. However, because we combined studies that reported complications somewhat differently (patients vs events), this involves an assumption that the two types of data will produce a similar effect. Although no heterogeneity was detected, we chose not to present a quantitative summary estimate for this outcome.

The studies were then pooled in a random-effects meta-analysis to reach a qualitative conclusion. Pooling these studies showed a statistically significant reduction in total complications associated with Doppler-monitored fluid replacement (see Table 7 below). Our sensitivity analysis for qualitative robustness indicated that the summary effect size is qualitatively robust (i.e., the effect of Doppler monitoring is greater than zero) (Table D-13, Appendix D). Therefore, the strength of evidence supporting the qualitative conclusion (that Doppler-guided fluid replacement during surgery leads to a clinically significant reduction in the total number of complications compared to the control protocol) is strong. This conclusion only applies to patients undergoing surgical procedures with an expected substantial blood loss or fluid compartment shifts requiring fluid replacement.

Table 7 Meta-analysis – Total Complications (EDM + CVP + Conventional Assessment vs. CVP + Conventional Assessment)

Study | N = | Effect Size | Lower 95% CI | Upper 95% CI | p-value | I^2^ | Forest Plot
| | | | | | | [image]
Noblett et al.(42) | 103 | −0.76 | −1.60 | 0.07 | 0.07 | NA | [image]
Wakeling et al.(43) | 128 | −0.89 | −1.60 | −0.18 | 0.01 | NA | [image]
Conway et al.(44) | 57 | −0.82 | −2.07 | 0.43 | 0.20 | NA | [image]
Gan et al.(11) | 100 | −1.48 | −2.33 | −0.62 | 0.0008 | NA | [image]
Random-effects log odds ratio | 388 | NC | −1.43 | −0.57 | 0.000006 | 0% | [image]

NA Not Applicable

##### Length of Hospital Stay

All of the included studies reported length of hospital stay. Individual study data appear in Table D-10, Appendix D. The mean or median length of stay varied somewhat among the studies. Gan et al. reported the shortest mean hospital stay (average five to seven days), while Conway et al. reported the longest (12 to 18 days). This could have been due to differences in age and/or surgical procedures in different trials (e.g., the patients in Gan’s trial had the lowest average age). Four of the five studies found a statistically significant reduction in length of stay (based on either medians or means) associated with Doppler-monitored fluid replacement (Table D-10, Appendix D). Because a precise effect size could not be calculated from three studies (data were not reported as means with standard deviations or 95% confidence intervals), we could not combine the results of these studies to obtain a quantitative summary estimate of the length of stay (we required that at least 80% of studies in the evidence base for a given outcome must provide data that allow calculation of a precise effect size). Therefore, no quantitative conclusion is possible for this outcome.

However, even if all of the studies had reported means and SDs, there is a legitimate concern that means may not be the best measure of central tendency (and the average patient experience) in these studies. In some studies the mean may be considerably skewed by outliers (as appears to be the case in the Conway study, discussed in more detail below). Therefore, the best measure of central tendency for length of stay appears to be the median. Although calculation of an effect size from medians and ranges (or interquartile ranges) requires certain assumptions, we decided to base our primary analysis of this outcome on medians and ranges when available (means and SDs were used otherwise).

We were able to impute an estimated effect size for studies that reported medians and ranges using the methods described by Hozo et al.(27) This allowed us to combine the results in a random effects meta-analysis to reach a qualitative conclusion. Because these imputation methods are conservative, the individual study effect sizes based on this method were not statistically significant in four out of five studies (in contrast to the p-values reported in the original studies, which were mostly based on non-parametric tests of the medians). However, the summary effect size was statistically significant and qualitatively robust as determined by multiple sensitivity analyses; the 95% CI of the summary effect never overlapped zero (Table D-14, Appendix D). The summary effect size also was qualitatively robust with respect to the line of clinical significance. In the primary meta-analysis, the 95% CI overlapped with the clinically significant level of one day (−0.57 days). Sensitivity analyses did not alter this finding, indicating uncertainty as to whether the true effect size was ≥ or < one day.

The study by Conway et al. was unique in that it was the only study that did not use a version of the CardioQ system. However, the apparent discrepancy between the results of this study and other studies may have been due predominantly to one outlying patient in the Doppler group. Although the means had not been reported in the original study (which had reported medians and ranges), the lead author sent us the unpublished means and standard deviations. Because one patient in the Doppler group stayed in the hospital 103 days (not because of complications, but because the hospital could not find social/community placement for the patient),(8) the difference between means in the two groups is substantially skewed in favor of the control group (the difference between medians was much smaller, only one day).

To further examine this issue, we performed a sensitivity analysis wherein we used the means from the two studies that reported both means and medians (in other words, means were used whenever possible). This analysis (shown in Table D-14, Appendix D) did not overturn the qualitative findings of the primary meta-analysis. Additional sensitivity analyses using more conservative assumptions for imputing standard deviations from ranges or IQRs also did not overturn the findings (Table D-14).

In summary, the strength of evidence supporting the qualitative conclusion that Doppler-monitored fluid replacement leads to a reduction in hospital stay (clinical significance uncertain) is strong. This conclusion only applies to patients undergoing surgical procedures with an expected substantial blood loss or fluid compartment shifts requiring fluid replacement.

#### Studies Comparing Esophageal Doppler Monitoring Plus Conventional Assessment to CVP Plus Conventional Assessment

One study (Venn et al.) compared esophageal Doppler-guided fluid replacement with CVP-guided fluid replacement in patients receiving hip surgery. This study differs from those in the previous section in that none of the patients in the Doppler-monitored group received CVP monitoring. Also, patients in this study received additional fluid challenges in both the Doppler and CVP groups, whereas patients in the control group in the previous section’s studies did not receive additional fluid challenges beyond that dictated by conventional protocol. The previous studies were basically asking whether Doppler monitoring is an effective complementary procedure to CVP plus conventional protocol, whereas the study by Venn et al. treats Doppler monitoring as a competing technology to CVP. However, the previous studies do not attempt fluid challenges in the CVP groups, whereas the Venn study presents a protocol for fluid challenges based solely on changes in CVP. An ideal study might be a three-armed study comparing a fluid challenge protocol based on Doppler plus CVP to fluid challenge protocols based on CVP alone and esophageal Doppler alone.

##### Mortality

Although the study by Venn et al. had half as many deaths in the Doppler group compared to the CVP group, the difference was not statistically significant (3 vs. 6, p = 0.30, see Table D-7, Appendix D). Because the difference between the upper and lower 95% confidence intervals around the effect size exceeded 0.8 (using the log odds ratio), this result was not informative. Therefore, no conclusion could be reached for this outcome.

##### Major Complications

This study did not separate major complications from total complications, so no conclusion was possible for this outcome.

##### Total Complications

The difference in the rate of total complications (comprised mostly of infections and cardiovascular events) between the Doppler-monitored and CVP-monitored groups was not statistically significant (46.7% vs. 51.6%, p = 0.70, see Table D-9, Appendix D) and not informative for the reason cited above. Thus, no conclusion was possible for this outcome.

##### Length of Hospital Stay

The mean length of hospital stay did not differ significantly between the Doppler-monitored and CVP-monitored groups (13.5 vs. 13.3 days, p = 0.96, see Table D-10, Appendix D), and the effect size was non-informative. Therefore, no conclusion could be reached for this outcome.

#### Studies Comparing Esophageal Doppler Monitoring Plus Conventional Assessment to Conventional Assessment

##### Mortality

Both studies (Venn et al and Sinclair et al) reported total mortality rates (for individual study data, see Table D-7, Appendix D). Six of the eight deaths occurred during the early post-operative period (within 30 days following surgery), while two deaths occurred after this period (within three months following surgery). Neither study showed a statistically significant difference in mortality rates between the two treatment groups. The pooled mortality difference derived from a random-effects meta-analysis was not informative (not statistically significant and having very large confidence intervals), so no conclusion was possible for this outcome.

##### Major Complications

One study (Sinclair et al) did not report complications, and the other (Venn et al) did not separate major complications from total complications. Therefore, no conclusion was possible for this outcome.

##### Total Complications

Only one of the studies (Venn et al.) reported total complication rates; data are presented in Table D-9, Appendix D. The between-group difference was statistically significant and favored fewer complications in the Doppler-monitored group (46.7% vs. 79.3%, p = 0.015). However, the difference in the percentage of patients with complications was not quite statistically significant (33.3% vs 55.2%, p = 0.09), although the percentage was lower in the Doppler group. This was a high-quality study, but the magnitude of effect was not large enough to meet our predetermined definition of a large effect (see Appendix B, Decision Point 10), and therefore we do not draw a conclusion about the strength of the evidence based on this single study.

##### Length of Hospital Stay

Both studies reported length of hospital stay (see Table D-10 in Appendix D for individual study results). Both studies reported a shorter length of stay among patients receiving Doppler-monitored fluid replacement, but the difference was statistically significant only in the study by Sinclair et al. Because the information in this study did not allow calculation of an accurate effect size, we imputed an effect size based on the reported medians and interquartile ranges. This allowed us to pool the results of both studies in a random-effects meta-analysis. The summary effect size was statistically significant (p = 0.008) and favored a shorter hospital stay among patients in the Doppler-monitored group (Table D-11, Appendix D). Because the lower 95% confidence interval of the summary effect was above one day (1.75 days), the difference between groups was clinically significant by our definition. The low number of studies precluded a quantitative conclusion but allowed us to reach a qualitative conclusion. Since the quality of these studies is high, and the magnitude of effect is not large, the strength of evidence supporting the qualitative conclusion that esophageal Doppler monitoring without CVP leads to a clinically significant reduction in hospital stay is weak. This conclusion only applies to patients undergoing surgical procedures with an expected substantial blood loss or significant fluid shifts requiring fluid replacement.

### Subsection Summary

After searching the literature, retrieving articles, and applying the inclusion/exclusion criteria, we identified seven studies that addressed Key Question 2. Five compared esophageal Doppler monitoring plus CVP monitoring plus conventional clinical assessment to CVP plus conventional clinical assessment for optimization of fluid replacement during surgery. The median quality of these five studies was high, and the age-applicability to the Medicare population was fair. The remaining two studies compared the efficacy of esophageal Doppler monitoring plus conventional clinical assessment to conventional clinical assessment to optimize intravenous fluid replacement (one of these studies also compared esophageal Doppler to CVP plus conventional clinical assessment). The median quality of these two studies and their age-applicability to the Medicare population was high.

The addition of esophageal Doppler monitoring for guided fluid replacement to a protocol using CVP and conventional clinical assessment during surgery leads to a clinically significant reduction in the rate of major complications and total complications in surgical patients compared to CVP plus conventional clinical assessment alone. The strength of evidence supporting this conclusion is strong. Because only three of five studies separately reported major complications, and because of differences in the way total complications were reported, no quantitative conclusion is presented for these outcomes.

The addition of esophageal Doppler monitoring to CVP plus conventional assessment also reduces the length of hospital stay for surgical patients (clinical significance uncertain). The strength of evidence supporting this conclusion is strong. The lack of a calculable precise effect size in three studies precluded a quantitative summary estimate of the reduction in length of stay.

Only one study compared esophageal Doppler plus conventional clinical assessment to CVP plus conventional clinical assessment. Because this was one small study with non-informative effect sizes, no conclusions were possible for any of the outcomes of interest.

The addition of esophageal Doppler monitoring for guided fluid replacement to conventional clinical assessment during surgery leads to a clinically significant reduction in the length of hospital stay compared to that associated with conventional clinical assessment alone. The strength of evidence supporting this conclusion is weak. The low number of studies precluded a quantitative estimate of the reduction in length of hospital stay. Because only a single study reported total complications, no conclusion was possible concerning this outcome.

No conclusion could be reached concerning relative mortality rates for any of the comparisons in Key Question 2.

The conclusions in this subsection only apply to patients undergoing surgical procedures with an expected substantial blood loss or significant fluid compartment redistribution requiring fluid replacement.

## Key Question 3 Does Therapeutic Management Based on Esophageal Doppler Ultrasound Cardiac Output Monitoring During Hospitalization Lead to Improved Patient Outcomes (Fewer Complications and Shorter Hospital Stay), Compared to Catheter-Based Measurement or Conventional Clinical Assessment?

### Evidence Base

Our searches identified one study (an RCT) that potentially met our a priori inclusion criteria and was therefore retrieved. This study of 174 patients was included and appears in Table 9 below. Details of this study are presented in Tables E-1 through E-3, Appendix E.

Table 9 Evidence Base for Key Question 3

Study Design | Treatment Comparison | References
Randomized controlled trials | EDM + CVP + conventional clinical assessment vs. CVP + conventional clinical assessment | McKendry et al. 2004(48)

EDM – Esophageal Doppler Monitoring

CVP – Central Venous Pressure Assessment

### Quality of Included Studies

The results of our analysis of the quality of the study by McKendry et al. are summarized in Table 10. We based the quality ratings for this study on the criteria and information presented in Table E-4 of Appendix E.

Table 10 Quality of Included Studies Addressing Key Question 3

Reference | Year | ECRI Quality Score (Rating)
McKendry et al. 2004(48) | 2004 | 8.5 (high)

### Details of Study Enrollees and Study Generalizability

Details about the patients enrolled by McKendry et al. are presented in Table E-1 to E-2 of Appendix E. This study allowed inclusion of patients 18 years or older, and the average age of included patients was 66 years. Therefore, some but not all patients were in the age range applicable to the Medicare population, so the age generalizability of this study was considered to be “Fair.”^3^ The estimated percentage of patients ≥65 years in this study appears in Table 11 below.

3 High = Characteristics of all enrolled patients typical of Medicare population; Fair = Characteristics of some enrolled patients typical of Medicare population; Poor = Characteristics of only a few enrolled patients typical of Medicare population or enrolled patients represent a subgroup of Medicare population.

Table 11 Age-Generalizability of Study to the Medicare Population

Reference | Year | Percentage of patients age 65 years and older | Age generalizability rating
McKendry et al.^a^ 2004(48) | 2004 | 54% | Fair

a The study reported only the means and SDs, so ECRI estimated this percentage by assuming a normal distribution of age.

### Findings of Included Studies

The only study that met our inclusion criteria (McKendry et al.) compared the efficacy of esophageal Doppler monitoring plus CVP plus conventional clinical assessment to CVP plus conventional clinical assessment for optimization of intravenous fluid replacement in patients admitted to cardiac intensive care following cardiac surgery. The specific individual complications reported are listed in Table E-5, Appendix E.

#### Mortality

McKendry et al. reported four deaths in the Doppler-monitored group and two deaths in the control group. The causes of death “were not considered directly attributable to early post-operative care”.(48) Although the difference in mortality rates was not statistically significant (p = 0.43), the 95% confidence intervals were so large that the finding could not be considered informative (Table E-6, Appendix E). Thus, no conclusion can be drawn concerning this outcome.

#### Major Complications

This study did not specifically separate major complications from total complications reported, although the authors stated that there was “a trend towards fewer major postoperative complications and deaths” in the Doppler-monitored group. It is possible that the authors considered all reported complications as major, but some of these complications (such as atrial fibrillation) would not have been considered major as defined by the trials in Key Question 2. Thus, no conclusion is possible for this outcome.

#### Total Complications

Although this study reported fewer patients with postoperative complications in the Doppler-monitored group (19.1% vs. 30.6% in control group), the difference was not statistically significant (p = 0.08). Furthermore, the 95% confidence intervals around the difference were too large to be considered informative (Table E-6, Appendix E). Therefore, no conclusion can be reached for this outcome.

#### Length of Hospital Stay

McKendry et al. reported a statistically significant reduction in median length of hospital stay in the Doppler-monitored group (7 vs. 9 days in control group, p = 0.02) (Table E-5, Appendix E). However, the mean difference in hospital stay (11.4 vs. 13.9 days) was apparently not statistically significant. Furthermore, although this is a high-quality study, the mean between-treatment difference of 2 to 2.5 days means that the treatment effect cannot be judged as “large” (this would have required a minimum difference of at least 3 days). Therefore, no conclusion can be reached for this outcome.

### Subsection Summary

After searching the literature, retrieving articles, and applying the inclusion/exclusion criteria, we identified one study that compared esophageal Doppler monitoring plus CVP plus conventional clinical assessment to CVP plus conventional clinical assessment for optimization of intravenous fluid replacement in patients admitted to intensive care following cardiac surgery. This study was judged to be of high quality based on ECRI ratings. Generalizability to the Medicare population was fair. However, this was a single small study without a demonstrably large treatment effect on the outcomes of interest. Therefore, no conclusions could be reached for this question.

## Key Question 4 What Complications, Harms, and Adverse Events Associated with Esophageal Doppler Ultrasound Monitoring Have Been Reported?

### Evidence Base

Our searches identified 75 studies that potentially addressed this question. Upon retrieval, 52 studies were found to either use TEE systems (rather than esophageal Doppler systems) or to contain no relevant information on complications and were therefore excluded. The remaining 23 studies that addressed this question are listed in Table 12.

Table 8 Individual Study Effect Sizes – Length of Hospital Stay (EDM + CVP + Conventional Assessment vs. CVP + Conventional Assessment)

Study | N = | Effect Size | Lower 95% CI | Upper 95% CI | p-value | I^2^ | Forest Plot
| | | | | | | [image]
Noblett et al.(42) | 103 | −2.00 | −4.61 | 0.61 | 0.13 | NA | [image]
Wakeling et al.(43) | 128 | −1.50 | −2.86 | −0.14 | 0.03 | NA | [image]
Conway et al.(44) | 57 | 1.00 | −8.14 | 10.14 | 0.83 | NA | [image]
Gan et al.(11) | 100 | −1.00 | −2.18 | 0.18 | 0.10 | NA | [image]
Mythen and Webb(45) | 60 | −3.70 | −7.56 | 0.16 | 0.06 | NA | [image]
Random effects 95% CI | 448 | NC | −2.21 | −0.57 | 0.0009 | NA | [image]

NA – Not applicable

NC – Not calculated

Table 12 Evidence Base for Key Question 4

Study Design | References
Randomized controlled trials | Noblett et al. 2006(42); Conway et al. 2002(44); Venn et al.(46); Sinclair et al.(47)
Case series^a^ | Cipolla et al. 2006(49); Collins et al. 2005(50); Koliopanos et al. 2005(51); Sawai et al. 2005(52); Sharma et al. 2005(53); Bein et al. 2004(54); Feldman et al. 2004(55); Iregui et al. 2003(56); Moxon et al. 2003(57); Seoudi et al. 2003(58); Su et al. 2002(59); Odenstedt et al. 2001(60); Madan et al. 1999(61); Elliott et al. 1998(62); Lefrant et al. 1998(18); Valtier et al. 1998(63); Singer et al. 1989(64)
Case reports | Chandan and Hull 2004(65)

a Some of these studies compared the accuracy of esophageal Doppler monitoring to other methods (e.g., thermodilution) within the same patient. However, for the purposes of evaluating esophageal probe-related complications, these studies are equivalent to case series (because every patient received esophageal Doppler probes).

### Quality of Included Studies

Because the intent of this question is simply to list reported harms of esophageal Doppler ultrasound probes from any available data sources, we have not formally evaluated the quality of the evidence for this question. Uncontrolled studies or case reports cannot be used to determine causality or to estimate frequencies of adverse events; they can only be used to generate a list of adverse events possibly attributable to the device.

### Details of Study Enrollees and Study Generalizability

For the reason described under quality of included studies, we do not present details of study enrollees or make judgments about study generalizability for the studies addressing this question.

### Findings of Included Studies

Our searches identified one publication that reported two case reports of incorrect placement of an esophageal Doppler probe in the left main bronchus.(65) This led to adverse symptoms in only one of these patients. The cases are described in more detail in Table 9. An additional study of 106 critically ill patients reported accidental removal of an orogastric tube during esophageal probe removal. A study of 13 patients reported incorrect placement of an esophageal Doppler probe in one patient’s trachea, but this did not cause any adverse effect. Finally, a study of 60 patients mentioned “occasional minimal trauma in the buccal cavity during placement of the esophageal probe” but did not state the number of patients who experienced this problem.

Our searches also identified 19 studies (4 RCTs and 15 case series) with a total of 654 patients that specifically stated that esophageal Doppler probes led to no complications in any of the patients included in these studies. The studies are listed in Table F-1, Appendix F.

Another 33 studies that were retrieved did not report whether any complications were associated with esophageal Doppler probes. Without a statement to the effect that no complications occurred, one cannot determine whether the authors simply did not report complications or whether no complications occurred in these studies.

Our search of the FDA’s Manufacturer and User Facility Device Experience (MAUDE) database identified only one report of a mechanical problem with the CardioQ Doppler probe. While a nurse was cleaning one of these probes with a tissue, the probe boot (distal end of the probe) separated from the rest of the probe body. However, this particular probe did not cause any complication in a patient.

It is noteworthy that no case of an esophageal or pharyngeal perforation has yet been reported in association with an esophageal Doppler probe. As noted in Key Question 1, such perforations have occasionally occurred during use of TEE probes. This may be because traditional TEE probes are larger than esophageal Doppler probes and tend to undergo more manipulation during monitoring.

Table 13 Studies Reporting Complications Associated with Esophageal Doppler Probes

References | Esophageal Doppler Probe (manufacturer) | Description of cases
Chandan and Hull 2004(65) | CardioQ (Deltex Medical) | A 68-year old man had increasing airway resistance and oxygen requirement several hours after insertion of the esophageal probe. A chest x-ray showed the probe to be in the left main bronchus, and it was promptly removed. The x-ray also showed increased pulmonary shadowing in the lower zones consistent with aspiration of regurgitated gastric fluid. It is likely that the esophageal Doppler probe caused the tracheal tube cuff to become incompetent. A 73-year old man received a chest x-ray for respiratory system review. The esophageal Doppler probe was found in the left main bronchus and promptly removed. There were no other changes to alert the staff to the incorrect placement of the probe.
Iregui et al. 2003(56) | ODM I (Deltex Medical) (earlier model of CardioQ) | In this study of 106 critically ill ICU patients, 1 patient had unintentional removal of an orogastric tube during removal of the esophageal Doppler probe. Forty patients received additional sedation during probe placement, but no side effects were reported.
Moxon et al. 2003(57) | HemoSonic 100 (Arrow International) | In this study of 13 patients, the esophageal Doppler probe was accidentally placed in the trachea in 1 patient. This was immediately recognized and corrected by the clinicians, and did not cause an adverse effect. No other complications were reported.
Singer et al. 1989(64) | Prototype esophageal transducer | In this study of 60 patients, no complications occurred other than occasional minimal trauma in the buccal cavity during placement of the esophageal probe (number of patients with minimal trauma not reported).

### Subsection Summary

Currently, no serious adverse events associated with esophageal probes have been reported in the literature or the MAUDE database. The only minor events identified included two cases of incorrect probe placement in the left main bronchus, one case of incorrect placement in the trachea, a tube displacement during probe removal, and an unspecified number of cases of minimal trauma in the buccal cavity during probe placement. Nineteen studies with a total of 654 patients specifically stated that esophageal Doppler probes did not cause any complications. The number of patients represented in these studies is relatively small. However, the available evidence suggests that esophageal Doppler probes are relatively low-risk devices, as reporting of even minor morbidity has been infrequent thus far.

## Conclusions

### Conclusions for Key Question 1

Several methods are currently used to monitor cardiac output in patients during surgery or intensive care. These methods include thermodilution, dye dilution, lithium dilution, methods using the Fick principle, pulse contour methods, thoracic electrical bioimpedance, transesophageal echocardiography, and esophageal Doppler monitoring.

### Conclusions for Key Question 2

The addition of esophageal Doppler monitoring for guided fluid replacement to a protocol using CVP and conventional clinical assessment during surgery leads to a clinically significant reduction in the rate of major and total complications in surgical patients compared to CVP plus conventional clinical assessment alone. The strength of evidence supporting this conclusion is strong. Because only three of five studies separately reported major complications, and because of differences in the way total complications were reported, no quantitative conclusion is presented for these outcomes.

The addition of esophageal Doppler monitoring to the protocol described above also reduces the length of hospital stay for surgical patients (clinical significance uncertain). The strength of evidence supporting this conclusion is strong. The lack of a calculable precise effect size in some studies precluded a quantitative summary estimate of the reduction in length of stay.

Only one study compared esophageal Doppler plus conventional clinical assessment to CVP plus conventional clinical assessment. Because this was one small study with non-informative effect sizes, no conclusions were possible for any of the outcomes of interest.

The addition of esophageal Doppler monitoring for guided fluid replacement to conventional clinical assessment during surgery leads to a clinically significant reduction in the length of hospital stay compared to conventional clinical assessment alone. The strength of evidence supporting this conclusion is weak. The low number of studies precluded a quantitative estimate of the reduction in length of hospital stay. Because only a single study reported total complications, no conclusion was possible concerning this outcome.

No conclusion could be reached concerning relative mortality rates for any of the comparisons in Key Question 2.

The conclusions for Key Question 2 only apply to patients undergoing surgical procedures with an expected substantial blood loss or significant fluid compartment shifts requiring fluid replacement.

### Conclusions for Key Question 3

The evidence base contained only one small study that was insufficient to allow conclusions to be reached about the effectiveness of esophageal Doppler monitoring in hospitalized patients in nonoperative settings.

### Conclusions for Key Question 4

Currently, no serious adverse events associated with esophageal probes have been reported in the literature or the MAUDE database. The only minor events identified included two cases of incorrect probe placement in the left main bronchus, one case of incorrect placement in the trachea, a tube displacement during probe removal, and an unspecified number of cases of minimal trauma in the buccal cavity during probe placement. Nineteen studies with a total of 654 patients specifically stated that esophageal Doppler probes did not cause any complications. The number of patients represented in these studies is relatively small. However, the available evidence suggests that esophageal Doppler probes are relatively low-risk devices, as reporting of even minor morbidity has been infrequent thus far.