# Bibliography

1 Cholley BP, Singer M. Esophageal Doppler: noninvasive cardiac output monitor. Echocardiography. Nov. 2003;20(8):763-9. [pmid: 14641384].
2 Cholley BP, Payen D. Noninvasive techniques for measurements of cardiac output. Curr Opin Crit Care. Oct. 2005;11(5):424-9. [pmid: 16175028].
3 Price JD, Sear JW, Venn RM. Perioperative fluid volume optimization following proximal femoral fracture. The Cochrane Database of Systematic Review. 2004;(1). [database online]. Hoboken (NJ). John Wiley & Sons, Ltd. [Art No: CD003004] Available. [doi: 10.1002/14651858.CD003004.pub2].
4 Hocking G. Central venous access and monitoring. Update Anaesthesia. 2000;(12). article 13. Also available: http://www.nda.ox.ac.uk/wfsa/html/u12/u1213_01.htm.
5 Vinayak AG, Levitt J, Gehlbach B, Pohlman AS, Hall JB, Kress JP. Usefulness of the external jugular vein examination in detecting abnormal central venous pressure in critically ill patients. Arch Intern Med. Oct. 23. 2006;166(19):2132-7. [pmid: 17060544].
6 Cardiac output. [internet]. St. Petersburg (FL). Wikimedia Foundation Inc. 2006. May. 13. accessed 2006 Jun 2. 5 p. Available: http://en.wikipedia.org/wiki/Cardiac_output.
7 Hett DA, Jonas MM. Non-invasive cardiac output monitoring. Intensive Crit Care Nurs. Apr. 2004;20(2):103-8. [pmid: 15072778].
8 Conway D, Consultant in Anaesthesia & Intensive Care. Manchester Royal Infirmary. Manchester, UK. Personal communication. 2006. 6 p.
9 Venn R. Consultant in Anesthesia & Intensive Care. Worthing Hospital, Worthing UK. Personal communication. 2006. 4 p.
10 Dark PM, Singer M. The validity of trans-esophageal Doppler ultrasonography as a measure of cardiac output in critically ill adults. Intensive Care Med. Nov. 2004;30(11):2060-6. [pmid: 15368037].
11 Gan TJ, Soppitt A, Maroof M, el-Moalem H, Robertson KM, Moretti E, Dwane P, Glass PS. Goal-directed intraoperative fluid administration reduces length of hospital stay after major surgery. Anesthesiology. Oct. 2002;97(4):820-6. [pmid: 12357146].
12 Laupland KB, Bands CJ. Utility of esophageal Doppler as a minimally invasive hemodynamic monitor: a review. Can J Anaesth. 2002;49(4):393-401. [pmid: 11927480].
13 Deltex Medical Group plc, preliminary results for year ended 31 December 2005. Chichester, UK. Deltex Medical Group. 2005. 14 p.
14 510(k) premarket notification database. [database online]. Rockville (MD). U.S. Food and Drug Administration, Center for Devices and Radiological Health. Nov. 7. [updated 2006 Oct 6]. accessed 2006 Oct 9. Flowmeter, blood, cardiovascular. K951369. 1995:1. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=95874.
15 510(k) summary. CardioQ cardiac output and fluid status monitoring system. K031706. Chichester, UK. Deltex Medical Limited. 2003. Aug. 6. 8 p.
16 Sometic Inc. 510(k) premarket notification database. Flowmeter, blood, cardiovascuar. Dynemo 3000. K972798. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA). 1998. 2 p. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=114313.
17 Deltex Medical Group. Acquisition of TECO. Chichester (UK). Deltex Medical Group plc. 2006. Feb. 7. 2 p.
18 Lefrant JY, Bruelle P, Aya AG, Saissi G, Dauzat M, de La Coussaye JE, Eledjam JJ. Training is required to improve the reliability of esophageal Doppler to measure cardiac output in critically ill patients. Intensive Care Med. Apr. 1998;24(4):347-52. [pmid: 9609413].
19 NCD for ultrasound diagnostic procedures (220.5). [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). accessed 2005 Sep 23. 3 p.
20 Aetna. Clinical policy bulletin number: 0008. Color-flow doppler echocardiography in adults. [internet]. Hartford (CT). Aetna, Inc. 2006. Jun. 9. accessed 2006 Jun 20. 6 p. Available: http://www.aetna.com/cpb/data/CPBA0008.html.
21 Blue Cross and Blue Shield of Massachusetts. Echocardiography. Policy no. 108. [internet]. Rockland (MA). Blue Cross and Blue Shield of Massachusetts. 2006. May. 16. accessed 2006 Jun 20. 7 p. Available: http://www.bluecrossma.com/common/en_US/medical_policies/108%20Echocardiography%20prn.pdf.
22 Blue Cross and Blue Shield of North Carolina. Intraoperative transesophageal echocardiography. Policy No. SUR6410. [internet]. Durham (NC). Blue Cross and Blue Shield of North Carolina. 1996. Apr. 1. [updated 2005 Oct 8]. accessed 2006 Jun 20. 5 p. Available: http://www.bcbsnc.com/services/medical-policy/pdf/intraoperative_transesophageal_echocardiography.pdf.
23 Moher D, Pham, Klassen TP, Schulz KF, Berlin JA, Jadad AR, Liberati A. What contributions do languages other than english make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
24 Juni P, Holenstein F, Sterne J, Bartlett C, Egger M. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
25 Atkins D, Best D, Briss PA, Eccles M, Falck-Ytter Y, Flottorp S, Guyatt GH, Harbour RT, Haugh MC, Henry D, Hill S, Jaeschke R, Leng G, Liberati A, Magrini N, Mason J, Middleton P, Mrukowicz J, O’Connell D, Oxman AD, Phillips B, Schunemann HJ, Edejer TT, Varonen H, Vist GE, Williams JW Jr, Zaza S. Grading quality of evidence and strength of recommendations. BMJ. Jun. 19. 2004;328(7454):1490. Also available: http://bmj.bmjjournals.com/cgi/reprint/328/7454/1490. [pmid: 15205295].
26 Snedecor GW, Cochran WG. Statistical methods. 8th ed. Ames (IA). Iowa State University Press. 1989. 503 p.
27 Pudar Hozo S, Djulbegovic B, Hozo I. Estimating the mean and variance from the median, range, and the size of a sample. BMC Med Res Methodol. Apr. 20. 2005;5(1):13. [pmid: 15840177].
28 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
29 Hedges LV. Fixed effects models. Cooper H, Hedges LV, editors. The handbook of research synthesis. New York (NY). Russell Sage Foundation. 1994:285-99.
30 Olkin I. Diagnostic statistical procedures in medical meta-analysis. Stat Med. Sep. 15. 1999;18(17–18):2331-41. [pmid: 10474143].
31 Alberta Heritage Foundation for Medical Research. USCOM for cardiac output monitoring. Edmonton, Alberta. Alberta Heritage Foundation for Medical Research. 2006. May. 17 p. p. (TechNote Series; no. 56).
32 Thermodilution. [internet]. Biology-Online.org. 2005. Oct. accessed 2006 Jun 1. 1 p. Available: http://www.biology-online.org.
33 Gawlinski A. Measuring cardiac output: intermittent bolus thermodilution method. [internet]. Aliso Viejo (CA). American Association of Critical-Care Nurses (AACN). 2004. Oct. accessed 2006 Jun 1. 5 p. Available: http://www.findarticles.com/articles/mi_m0NUC/is_5_24/ai_n6332747/print.
34 Ott K, Johnson K, Ahrens T. New technologies in the assessment of hemodynamic parameters. J Cardiovasc Nurs. Jan. 2001;15(2):41-55. [pmid: 11140423].
35 Cardiac output measurement by indicator dilution. [internet]. Victoria (AU). Australasian Society of Cardio-Vascular Perfusionists. accessed 2006 Jun 5. 3 p. Available: http://www.perfusion.com.au.
36 LiDCO plus frequently asked questions & features and benefits. [internet]. Cambridge (UK). LiDCO Ltd. accessed 2006 Jun 5. 8 p. Available: http://www.lidco.com/html/technology/faqs.asp.
37 Berton C, Cholley B. Equipment review: new techniques for cardiac output measurement--oesophageal Doppler, Fick principle using carbon dioxide, and pulse contour analysis. Crit Care. Jun. 2002;6(3):216-21. [pmid: 12133181].
38 Scolletta S, Romano SM, Biagioli B, Capannini G, Giomarelli P. Pressure recording analytical method (PRAM) for measurement of cardiac output during various haemodynamic states. Br J Anaesth. Aug. 2005;95(2):159-65. [pmid: 15894561].
39 Humana. Thoracic electrical bioimpedance (impedance cardiography). [internet]. Louisville (KY). Humana, Inc. 2004. Oct. 21. accessed 2006 Jun 7. 5 p. Available: http://www.humana.com.
40 Min JK, Spencer KT, Furlong KT, DeCara JM, Sugeng L, Ward RP, Lang RM. Clinical features of complications from transesophageal echocardiography: a single-center case series of 10,000 consecutive examinations. J Am Soc Echocardiogr. Sep. 2005;18(9):925-9. [pmid: 16153515].
41 Tan HL, Pinder M, Parsons R, Roberts B, van Heerden PV. Clinical evaluation of USCOM ultrasonic cardiac output monitor in cardiac surgical patients in intensive care unit. Br J Anaesth. Mar. 2005;94(3):287-91. [pmid: 15653709].
42 Noblett SE, Snowden CP, Shenton BK, Horgan AF. Randomized clinical trial assessing the effect of doppler-optimized fluid management on outcome after elective colorectal resection. Br J Surg. Sep. 2006;93(9):1069-76. [pmid: 16888706].
43 Wakeling HG, McFall MR, Jenkins CS, Woods WG, Miles WF, Barclay GR, Fleming SC. Intraoperative oesophageal Doppler guided fluid management shortens postoperative hospital stay after major bowel surgery. Br J Anaesth. Nov. 2005;95(5):634-42. [pmid: 16155038].
44 Conway DH, Mayall R, Abdul-Latif MS, Gilligan S, Tackaberry C. Randomised controlled trial investigating the influence of intravenous fluid titration using oesophageal Doppler monitoring during bowel surgery. Anaesthesia. Sep. 2002;57(9):845-9. [pmid: 12190747].
45 Mythen MG, Webb AR. Perioperative plasma volume expansion reduces the incidence of gut mucosal hypoperfusion during cardiac surgery. Arch Surg. Apr. 1995;130(4):423-9. [pmid: 7535996].
46 Venn R, Steele A, Richardson P, Poloniecki J, Grounds M, Newman P. Randomized controlled trial to investigate influence of the fluid challenge on duration of hospital stay and perioperative morbidity in patients with hip fractures. Br J Anaesth. Jan. 2002;88(1):65-71. [pmid: 11881887].
47 Sinclair S, James S, Singer M. Intraoperative intravascular volume optimisation and length of hospital stay after repair of proximal femoral fracture: randomised controlled trial. BMJ. Oct. 11. 1997;315(7113):909-12. [pmid: 9361539].
48 McKendry M, McGloin H, Saberi D, Caudwell L, Brady AR, Singer M. Randomised controlled trial assessing the impact of a nurse delivered, flow monitored protocol for optimisation of circulatory status after cardiac surgery. BMJ. Jul. 31. 2004;329(7460):258. [pmid: 15242867].
49 Cipolla J, Stawicki S, Spatz D. Hemodynamic monitoring of organ donors: a novel use of the esophageal echo-Doppler probe. Am Surg. Jun. 2006;72(6):500-4. [pmid: 16808202].
50 Collins S, Girard F, Boudreault D, Chouinard P, Normandin L, Couture P, Caron M-J, Ruel M. Esophageal doppler and thermodilution are not interchangeable for determination of cardiac output. Can J Anaesth. 2005;52(9):978-85. [pmid: 16251566].
51 Koliopanos A, Zografos G, Skiathitis S, Stithos D, Voukena V, Karampinis A, Papastratis G. Esophageal Doppler (ODM II) improves intraoperative hemodynamic monitoring during laparoscopic surgery. Surg Laparosc Endosc Percutan Tech. Dec. 2005;15(6):332-8. [pmid: 16340564].
52 Sawai T, Nohmi T, Ohnishi Y, Takauchi Y, Kuro M. Cardiac output measurement using the transesophageal Doppler method is less accurate than the thermodilution method when changing PaCO2. Anesth Analg. Dec. 2005;101(6):1597-601. [pmid: 16301225].
53 Sharma J, Bhise M, Singh A, Mehta Y, Trehan N. Hemodynamic measurements after cardiac surgery: transesophageal Doppler versus pulmonary artery catheter. J Cardiothorac Vasc Anesth. Dec. 2005;19(6):746-50. [pmid: 16326299].
54 Bein B, Worthmann F, Tonner PH, Paris A, Steinfath M, Hedderich J, Scholz J. Comparison of esophageal Doppler, pulse contour analysis, and real-time pulmonary artery thermodilution for the continuous measurement of cardiac output. J Cardiothorac Vasc Anesth. Apr. 2004;18(2):185-9. [pmid: 15073709].
55 Feldman LS, Anidjar M, Metrakos P, Stanbridge D, Fried GM, Carli F. Optimization of cardiac preload during laparoscopic donor nephrectomy: a preliminary study of central venous pressure vs esophageal Doppler monitoring. Surg Endosc. 2004;18(3):412-6. [pmid: 14716541].
56 Iregui MG, Prentice D, Sherman G, Schallom L, Sona C, Kollef MH. Physicians’ estimates of cardiac index and intravascular volume based on clinical assessment versus transesophageal Doppler measurements obtained by critical care nurses. Am J Crit Care. Jul. 2003;12(4):336-42. [pmid: 12882064].
57 Moxon D, Pinder M, van Heerden PV, Parsons RW. Clinical evaluation of the HemoSonic monitor in cardiac surgical patients in the ICU. Anaesth Intensive Care. Aug. 2003;31(4):408-11. [pmid: 12973965].
58 Seoudi HM, Perkal MF, Hanrahan A, Angood PB. The esophageal Doppler monitor in mechanically ventilated surgical patients: does it work?. J Trauma. Oct. 2003;55(4):720-5. discussion 725–6. [pmid: 14566129].
59 Su NY, Huang CJ, Tsai P, Hsu YW, Hung YC, Cheng CR. Cardiac output measurement during cardiac surgery: esophageal Doppler versus pulmonary artery catheter. Acta Anaesthesiol Sin. 2002;40(3):127-33. [pmid: 12434609].
60 Odenstedt H, Aneman A, Oi Y, Svensson M, Stenqvist O, Lundin S. Descending aortic blood flow and cardiac output: a clinical and experimental study of continuous oesophageal echo-Doppler flowmetry. Acta Anaesthesiol Scand. Feb. 2001;45(2):180-7. [pmid: 11167163].
61 Madan AK, UyBarreta VV, Aliabadi-Wahle S, Jesperson R, Hartz RS, Flint LM, Steinberg SM, Dulchavsky SA, Kuwagata Y, Bergstein J. Esophageal doppler ultrasound monitor versus pulmonary artery catheter in the hemodynamic management of critically III surgical patients. J Trauma Inj Infect Crit Care. 1999;46(4):607-12.
62 Elliott S, Savill P, Eckersall S. Cardiovascular changes during laparoscopic cholecystectomy: a study using transoesophageal Doppler monitoring. Eur J Anaesthesiol. Jan. 1998;15(1):50-5. [pmid: 9522141].
63 Valtier B, Cholley BP, Belot JP, de la Coussaye JE, Mateo J, Payen DM. Noninvasive monitoring of cardiac output in critically ill patients using transesophageal Doppler. Am J Respir Crit Care Med. Jul. 1998;158(1):77-83. [pmid: 9655710].
64 Singer M, Clarke J, Bennett ED. Continuous hemodynamic monitoring by esophageal Doppler. Crit Care Med. May. 1989;17(5):447-52. [pmid: 2651004].
65 Chandan GS, Hull JM. Incorrectly placed oesophageal Doppler probe. Anaesthesia. 2004;59:723. [pmid: 15200554].
66 West S, King V, Carey TS, Lohr KN, McKoy N, Sutton SF, Lux L. Systems to rate the strength of scientific evidence. (Prepared by Research Triangle Institute - University of North Carolina Evidence-based Practice Center under Contract no. 290-97-0011). AHRQ Publication no. 02-E016. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). 2002. Apr. 199 p. (Evidence report/technology assessment; no. 47). Also available: http://www.ncbi.nlm.nih.gov/books/bv.fcgi?rid=hstat1.chapter.70996.
67 Higgins JP, Thompson SG. Controlling the risk of spurious findings from meta-regression. Stat Med. Jun. 15. 2004;23(11):1663-82. [pmid: 15160401].
68 Harbord R. Statistical Software Components, Boston College Department of Economics. METAREG: Stata module to perform meta-analysis regression. [software download]. Stockholm, Sweden. EconPapers. 2004. Sep. 22. accessed 2004 Nov 3. Available: http://econpapers.hhs.se/software/bocbocode/s446201.htm.
69 Cochrane Collaboration. Cochrane reviewers’ handbook. Version 4.2.2. Oxford (UK). Cochrane Collaboration. 2004. Mar. 234 p. Also available: http://www.cochrane.org/resources/handbook/index.htm.
70 Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale (NJ). Lawrence Erlbaum Associates. 1988. 567 p.
71 Krishnamurthy B, McMurray TJ, McClean E. The peri-operative use of the oesophageal Doppler monitor in patients undergoing coronary artery revascularisation. A comparison with the continuous cardiac output monitor. Anaesthesia. Jul. 1997;52(7):624-9. [pmid: 9244018].