# Background

In this section, we provide background information on cardiac output monitoring and esophageal Doppler ultrasound. The purpose of this section is to provide context for the research syntheses presented later in this report. The information presented in this section may be based upon opinion, and we have not critically assessed its accuracy. This section is therefore not, in the strictest sense of the term, evidence-based. Consequently, no statement in this Background section should be interpreted as an endorsement or a criticism by ECRI.

## Intravenous Fluid Management

For patients in surgery or intensive care units, optimization of intravenous fluid replacement (colloid or crystalloid solutions) is essential to achieve maintenance of adequate organ perfusion. Ideally, this requires measurement of blood pressure and flow. Blood pressure must be sufficient to maintain a patent (open) vessel lumen, and blood flow must be sufficient to deliver adequate oxygen and metabolites to every cell (as well as remove metabolic byproducts such as CO_2_ and lactate).(1,2) If patients do not receive enough additional fluids, this can lead to hypovolemia (abnormally low levels of blood plasma) followed by hypotension and renal failure.(3) Conversely, addition of too much fluid may precipitate heart failure.

## Methods of Intravenous Fluid Management

### Conventional Clinical Assessment

Conventional clinical assessment usually refers to non-invasive assessment of various clinical markers. In some institutions, fluid management may be based only on assessment of hemodynamic variables such as heart rate, systolic blood pressure, and urinary output, with no measure of blood flow or central venous pressure (CVP).

### Central Venous Pressure (CVP) Monitoring

In addition to the conventional clinical assessment described above, some institutions will monitor CVP via a central venous catheter. CVP is a measure of the pressure in the right atrium.(4) Loss of fluid leads to a drop in CVP, while addition of fluid tends to increase CVP. This provides another measure to aid the physician in deciding how much additional fluid is required for individual patients in surgery or intensive care. Although CVP is usually measured with a catheter, some institutions may monitor CVP using a non-invasive method,(5) which is less accurate and is often incorporated in conventional clinical assessment.

### Cardiac Output Monitoring

Cardiac output refers to the amount of blood pumped by the heart per unit time, measured in liters per minute. It can be calculated by multiplying the stroke volume (the amount of blood pumped by the left ventricle in one contraction) and the heart rate.(6)

In theory, calculation of cardiac output may enable clinicians to more accurately titrate the level of additional fluids (colloid or crystalloid intravenous solutions) and vasoactive therapies to achieve adequate tissue perfusion. If the cardiac output does not increase after a fluid addition, this may indicate that the upper limit of fluid replacement has been achieved, and further fluid addition could lead to venous congestion and postoperative pulmonary edema.

Several methods are available for monitoring of cardiac output; the method generally used as a “reference” standard for other methods is thermodilution via a pulmonary artery catheter (see Key Question 1 for a detailed description of this and other methods for cardiac output monitoring). The use of pulmonary artery catheters carries a risk of serious complications, which has led some investigators to prefer less invasive methods of cardiac output measurement.

## Esophageal Doppler Monitoring

Esophageal Doppler monitoring is a relatively non-invasive technique used to measure cardiac output. A small probe is inserted into the esophagus of mechanically-ventilated patients, usually during anesthesia. The probe is introduced orally and advanced gently until its tip is located approximately at the mid-thoracic level, and then rotated so that it faces the descending aorta. The tip of the probe contains a Doppler transducer which transmits an ultrasound beam (4 MHz continuous-wave or 5 MHz pulsed-wave). The change in frequency of this beam as it reflects off a moving object allows measurement of blood flow velocity in the descending aorta. This measurement, when combined with an estimate of the cross-sectional area of the aorta, allows calculation of hemodynamic variables including stroke volume and cardiac output.(2,7) Potential limitations of esophageal Doppler monitoring include operator dependency, occasional difficulties in probe placement, difficulty interpreting the signal during periods of arrhythmia,(8) and the lack of central venous access (which can be obtained when using a pulmonary artery catheter to measure cardiac output). However, some practitioners do not consider lack of central venous access to be a limitation, as central venous catheters carry a risk of infection and other complications.(9)

Currently, the two most widely-used esophageal Doppler monitors are the CardioQ (Deltex Medical, Chichester, UK) and the HemoSonic 100 (Arrow International, Reading, PA). Each uses a different method for determination of stroke volume. The CardioQ uses a disposable 6 mm probe to measure blood flow in the descending thoracic aorta. A proprietary nomogram (factoring in patient age, weight, and height) is used to estimate the cross-sectional area in the descending aorta. The HemoSonic 100 uses a 7 mm non-disposable probe that requires a disposable sheath for each use. The probe contains two transducers, one measuring aortic blood flow and the other (known as an M-mode echo transducer) measuring the cross-sectional area of the descending aorta. The M-mode (or motion mode) transducer is further used to confirm probe placement by providing visualization of the walls of the descending aorta. M-mode technology is also used in transesophageal echocardiography (TEE). For this reason, the HemoSonic monitor is sometimes referred to as an echo-ED monitor.(1,10)

## Clinical Practice Guidelines

Our searches identified no clinical practice guidelines specifically focusing on the use of esophageal Doppler monitoring systems for optimization of fluid replacement in surgical or intensive care patients.

## Target Population

Despite the lack of clinical practice guidelines, inclusion/exclusion criteria and patient characteristics described in studies of cardiac output monitoring suggest that the authors in these studies reserved guided fluid replacement during surgery or intensive care for relatively higher-risk patients. They tend to be older patients, including some with co-morbid conditions, who require major surgical procedures (such as bowel resection, hip fracture repair, and cardiac surgery) with a significant anticipated blood loss.(8) One study’s inclusion criteria specified patients who were undergoing procedures where the anticipated blood loss was >500 ml.(11) Although most cardiac output monitoring studies do not specify an expected level of blood loss, they focus on procedures that are associated with high levels of blood loss necessitating fluid replacement. Cardiac output-guided fluid replacement is not generally considered for low-risk patients having ambulatory surgery.(8)

## Previous Systematic Reviews

The Cochrane Collaboration has published a systematic review titled “Perioperative fluid volume optimization following proximal femoral fracture”.(3) This review evaluated randomized controlled trials (RCTs) that compared different fluid optimization interventions, including esophageal Doppler monitoring. Two trials met the inclusion criteria; both compared esophageal Doppler monitoring to “usual care”, and one of the trials also compared central venous pressure (CVP) monitoring to “usual care”. The authors focused on patient-oriented outcomes such as mortality, complications, length of hospital stay, and independence in activities of daily living. They concluded that “invasive methods of fluid optimization (they consider esophageal Doppler an invasive method) during surgery may shorten hospital stay, but their effects on other important, patient-centred, longer-term outcomes are uncertain. Adverse effects on fatality cannot be excluded.” They further concluded that “more research is needed”.

Two additional systematic reviews have evaluated the agreement of esophageal Doppler monitoring and thermodilution via pulmonary artery catheter for measurement of cardiac output. One of these reviews was performed by investigators at the University of Manchester and University College London in the UK,(10) while the other was conducted by investigators at the University of Calgary (Alberta, Canada).(12) These reviews selected studies that compared agreement between measurements of the two techniques within the same patients. They did not evaluate the impact of these techniques on clinical outcomes (which would have required parallel control groups that each received a different monitoring method). The UK authors concluded that “the esophageal Doppler monitor has high validity (no bias and high clinical agreement with pulmonary artery thermodilution) for monitoring changes in cardiac output”. The Canadian authors concluded that esophageal Doppler “is a practical, reliable, and valid device for measuring cardiac output in perioperative and critically ill patients. Further studies with larger numbers of patients are needed to determine if the limited precision observed is inherent to the technique, the diagnoses of patients studied, or the small sample sizes.”

## Ongoing Trials

In a summary of preliminary results for the year 2005, Deltex Medical announced that the first multicenter RCT investigating the impact of CardioQ on death rates following emergency hip fracture repair would be initiated in 2006. The trial will involve more than 15 hospitals across France and is expected to be completed in three years. Dr. Bernard Cholley is the lead investigator. The number of patients to be enrolled and the control intervention were not mentioned.(13)

## Regulatory Issues

### Manufacturers and U.S. Food and Drug Administration (FDA) Status

The CardioQ cardiac output and fluid status monitoring system is manufactured by Deltex Medical Ltd. (Chichester, West Sussex, UK). The earliest model of this system (originally known as EDM) received FDA approval for marketing under the 510(k) process in November, 1995.(14) The later model (renamed CardioQ) received FDA approval for marketing under the 510(k) process in August, 2003.(15)

The Hemosonic 100 cardiac output monitor is manufactured by Arrow International (Reading, PA). This device received FDA approval for marketing under the 510(k) process in February, 1998 (originally approved as the Somatec, Inc. DYNEMO 3000).(16)

The TECO cardiac output monitoring system was manufactured by Medicina Ltd. (Oak House, Cookham, Berkshire, UK). This device was never approved for marketing in the U.S., but has been marketed in the U.K., Ireland, India, and China. In February 2006, Deltex Medical announced that it had purchased the TECO monitor business from Medicina Ltd.(17) Deltex Medical has no plans to market the TECO system, so it is no longer commercially available.

### Training and Credentialing

Our searches identified no formal guidelines for training and credentialing of esophageal Doppler system operators. However, a study by Lefrant et al. found that adequate training was achieved after the operator had used an esophageal Doppler device in 12 patients. Successful training was determined by the operator’s ability to get “a loud and clear Doppler signal with a well-defined sharp waveform”. Also, the correlation coefficient (r) for paired cardiac output measurements at different times in the same patients increased from 0.53 during the training period to 0.89 during the post-training period (r = 1 would be a perfect correlation).(18)

### Current CMS Policy Regarding Cardiac Output Monitoring with Doppler Ultrasound

Current CMS policy appears in the NCD for Ultrasound Diagnostic Procedures (220.5).(19) The benefit category is listed as Diagnostic Tests. The indications and limitations of coverage section divides these procedures into two categories. The NCD states that “Medicare coverage is extended to the procedures listed in Category I” provided that the techniques are “medically appropriate and the general indications specified in these categories are met. Techniques in Category II are considered experimental and should not be covered at this time.” Monitoring of cardiac output (Doppler) is currently listed in Category II (clinical reliability and efficacy not proven) and is thus ineligible for coverage at present.

### Third Party Payer Coverage

Our searches of ten company Web sites found three payers with coverage policies on topics related to esophageal Doppler monitoring, while seven payers had no coverage policy related to this technology. This is a representative but not comprehensive sample of coverage policies. Details about the payers with relevant coverage policies appear in Table 1; it is not clear that these policies include esophageal Doppler devices such as CardioQ. Payers that did not have relevant coverage policies include Blue Cross/Blue Shield of Alabama, Blue Cross/Blue Shield of Minnesota, Blue Cross/Blue Shield of Tennessee, Blue Cross/Blue Shield of Wisconsin, Cigna, Health Partners, and Humana. This does not necessarily mean that these companies do not provide reimbursement for esophageal Doppler monitoring; the procedure may be covered as part of a composite payment (DRG) for surgical or hospital services.

Table 1 Third Party Payer Coverage

Third Party Payer | Coverage Policy
Aetna(20) http://www.aetna.com/cpb/data/CPBA0008.html | The coverage policy is titled “Color-Flow Doppler Echocardiography in Adults”. It includes transesophageal Doppler echocardiography; however, it is not clear that the policy includes esophageal Doppler devices such as CardioQ. Aetna considers color-flow Doppler in adults medically necessary for the following indications:; - Evaluation of septal defects; - Evaluation of the severity of valve stenosis or regurgitation; - Evaluation of site of left-to-right or right-to-left shunts; - Assessment of diseases of the aorta; - Evaluation of prosthetic valves; Aetna considers color-flow Doppler in adults experimental and investigational for all other indications.
Blue Cross/Blue Shield of Massachusetts(21) http://www.bluecrossma.com/common/en_US/medical_policies/108%20Echocardiography%20prn.pdf | The coverage policy is titled “Echocardiography (including transesophageal echo, stress echo, bubble echo, color Doppler echo, fetal cardiac echo)”. It is not clear that esophageal Doppler devices are covered by this policy. Cardiac echocardiography in adults and children is covered for any indications, except when used as a screening test in the absence of signs or symptoms of a disease or condition.
Blue Cross/Blue Shield of North Carolina(22) http://www.bcbsnc.com/services/medical-policy/pdf/intraoperative_transesophageal_echocardiography.pdf | The coverage policy is titled “Intraoperative Transesophageal Echocardiography”. It is not clear that this policy covers use of esophageal Doppler systems. The policy provides a long list of surgical procedures for which intraoperative transesophageal echocardiography is covered, and a list of procedures for which use of this technology is not covered. The policy does not address non-operative usage of this technology.