# Evidence Tables for Key Question 4

Table F-1 Studies Reporting That Esophageal Doppler Monitoring Did Not Cause Any Complications

Reference | Year | Number of patients | Esophageal Doppler probe model (manufacturer)
Cipolla et al.(49) | 2006 | 6 | Hemosonic 100 (Arrow International)
Noblett et al.(42) | 2006 | 108 | CardioQ (Deltex Medical)
Collins et al.(50) | 2005 | 58 | Hemosonic 100 (Arrow International)
Koliopanos et al.(51) | 2005 | 55 | ODM II^a^ (Abbott Laboratories)
Sawai et al.(52) | 2005 | 30 | Hemosonic 100 (Arrow International)
Sharma et al.(53) | 2005 | 35 | TECO (Medicina Ltd)
Bein et al.(54) | 2004 | 10 | Hemosonic 100 (Arrow International)
Feldman et al.(55) | 2004 | 13 | Model not specified (Deltex Medical)
Seoudi et al.(58) | 2003 | 15 | Model EP90^a^ (Deltex Medical)
Conway et al.(44) | 2002 | 57 | TECO 2 (Medicina Ltd)
Su et al.(59) | 2002 | 24 | Hemosonic 100 (Arrow International)
Venn et al.(46) | 2002 | 30 | CardioQ (Deltex Medical)
Odenstedt et al.(60) | 2001 | 14 | Dynemo 3000^b^ (Somatec, Inc.)
Madan et al.(61) | 1999 | 14 | Model EP-90Q5^a^ (Deltex Medical)
Elliott et al.(62) | 1998 | 19 | ODM 2^a^ (Abbott Laboratories)
Lefrant et al.(18) | 1998 | 64 | ODM I^a^ (Deltex Medical)
Valtier et al.(63) | 1998 | 46 | ODM I a (Deltex Medical)
Krishnamurthy et al.(71) | 1997 | 16 | ODM II^a^ (Abbott Laboratories)
Sinclair et al.(47) | 1997 | 40 | ODM 2^a^ (Abbott Laboratories)

a Earlier models of CardioQ

b Earlier model of Hemosonic