# Evidence Tables for Key Question 3

Table E-1 Patient Enrollment Criteria for Studies Addressing Key Question 3

Reference | Year | Inclusion Criteria | Exclusion Criteria
McKendry et al.(48) | 2004 | Patients undergoing cardiopulmonary bypass surgery who had provided informed consent | Patients with age <18 years, those undergoing off-pump surgery, those who declined consent, or those with relative contraindications to use of the esophageal Doppler probe (esophageal varices or other oropharyngeal and esophageal disease).

NR Not Reported

Table E-2 Characteristics of Patients in Studies Addressing Key Question 3

Author/year | Year | Cardiac output monitoring procedure | N | Age (mean ±SD) | % female | ASA grade | Goldman cardiac risk index | POSSUM score | Hemoglobin level at baseline (g/dl) | % elective surgery
McKendry et al.(48) | 2004 | EDM (CardioQ) Conventional clinical protocol | 89 85 | 65.6 (10.3) 66.7 (10.2) | 37 33 | NR NR | NR NR | NR NR | NR NR | 88 84

NR Not Reported

Table E-3 Fluid Management Protocols in Studies Addressing Key Question 2

Reference | Year | Type of Surgery | Fluid management protocol for EDM group | Fluid management protocol for control group
McKendry et al.(48) | 2004 | Cardiopulmonary bypass surgery | Patients received continuous esophageal Doppler monitoring for first 4 h in intensive care following surgery. Patients received 200 ml fluid challenges (blood or colloid as appropriate), repeated until the stroke volume index increased to ≥35 ml/m^2^. Nitrates and inotropes were given as required. | Patients received conventional management as determined by intensive care and surgical teams (based primarily on monitoring arterial and CVP, but also cardiac output if considered clinically indicated). Doppler recordings were made within 10 minutes of admission to the intensive care unit and at 4 h post-operatively.

Table E-4 Study Quality Evaluation

ECRI study quality scale - questions | Study
ECRI study quality scale - questions | McKendry et al.
1. Were patients randomly assigned to groups? | Yes
2. Did the study emply stochastic randomization? | Yes
3. Were any methods used to make the groups comparable- randomization, matching, etc.? | Yes
4. Were patients assigned to groups based on factors other than patient or physician preference? | Yes
5. Were the characteristics of the patients in different groups comparable? | NR
6. Did the patients in the different study groups have similar levels of performance on outcomes at baseline? | Yes
7. Was the study prospectively planned? | Yes
8. Did 85% or more of the patients complete the study? | Yes
9. Was there a less than 16% difference in completion rates in the study’s groups? | Yes
10. Were all of the study’s groups concurrently treated? | Yes
11. Was compliance with treatment greater than or equal to 85% in both of the groups? | Yes
12. Were both groups treated at the same centers? | Yes
13. Were subjects blinded to treatment? | Yes
14. Did the authors test and confirm that blinding of patients was maintained? | NR
15. Was the treating physician blinded to group assignment? | No
16. Were the outcome assessors blinded to group assignment? | No
17. Was there concealment of allocation? | Yes
18. Was the outcome of interest objective and was it objectively measured?^a^ | Yes
19. Were the same methods used to measure outcomes in all of the study’s groups?^a^ | Yes
20. Was the instrument used to measure the outcome standard?^a^ | Yes
21. Was the same treatment given to all of the patients enrolled in the experimental group? | Yes
22. Was the same treatment given to all of the patients enrolled in the control group? | Yes
23. Were the follow-up times in all of the study’s relevant groups approximately equal? | Yes
24. Was the funding for this study derived from a source that does not have a financial interest in its results? | No
25. Were the author’s conclusions supported by the data in the results section? | Yes
Quality score | 8.5
Quality rating | High

Table E-5 Specific Complications Reported in Included Studies

Reference | Year | Type of Surgery | Reported complications
Noblett et al.(42) | 2006 | Cardiopulmonary bypass surgery | Death, atrial fibrillation requiring treatment, pneumothorax, cerebral vascular accident, chest infection, sternal wound infection, gastrointestinal bleed or perforated duodenal ulcer, acute renal failure, pleural effusion, infected leg wound, aortic regurgitation

Table E-6 Results of Study Addressing Key Question 3

Study | N | % total deaths (n/N) | | | % total complications (n/N) | | | Length of hospital stay (days)
Study | N | EDM group | Control group | p-value | EDM group | Control group | p-value | EDM group | Control group | p-value
McKendry et al.(48) | 174 | 4.5 (4/89) | 2.4 (2/85) | 0.68 | 19.1 (17/89) | 30.6 (26/85) | 0.08 | Mean: 11.4 Median: 7 | Mean: 13.9 Median: 9 | NR 0.02