# Evidence Tables for Key Question 2

Table D-1 Patient Enrollment Criteria for Studies Addressing Key Question 2

Reference | Year | Inclusion Criteria | Exclusion Criteria
Noblett et al.(42) | 2006 | Patients requiring elective bowel surgery | Severe esophageal disease, recent esophageal or upper airway surgery, systemic steroid medication, moderate or severe aortic valve disease, bleeding diathesis and patient choice.
Wakeling et al.(43) | 2005 | Patients requiring elective or semi-elective bowel surgery | Patients with age <18 years, hepatic pathology, perforated viscus, esophageal pathology, and coagulopathy
Conway et al.(44) | 2002 | Patients undergoing major bowel resections | Patients undergoing emergency, intrathoracic, or esophageal surgery, patients with known sensitivity to starch-based colloid or history of esophageal disease
Gan et al.(11) | 2002 | Patients with American Society of Anesthesiologists (ASA) physical status I, II, and III who were to undergo major elective general, urologic, or gynecologic surgery with an anticipated blood loss of >500 ml. | Patients with age <18 years, emergency surgery, preoperative bowel obstruction, coagulopathy, significant renal and hepatic dysfunction (creatinine >50% or liver enzymes >50% upper limit of normal values), congestive heart failure, and esophageal pathology (avoid potential complications of the esophageal probe), and those undergoing gastric or esophageal surgery or who were on antiemetic medication within 3 days of surgery
Venn et al.(46) | 2002 | Patients admitted with fractured hips | Patients with age <65 years, esophageal pathology, central venous cannula already in situ, pathological fracture of femur, refusal of informed consent, and those undergoing regional anesthesia
Sinclair et al.(47) | 1997 | Patients with fractures of the femoral neck of the hip | Patients with age <55 years, fracture secondary to neoplasm, fractures occurring during hospitalization for an acute illness, fracture through the site of a previous surgical correction or associated with instabiliy of a previous prosthesis, planned regional anesthesia (precluding placement of Doppler probe), and refusal of consent or inability to contact next of kin in the case of patietns unable to give consent themselves
Mythen and Webb(45) | 1995 | Patients scheduled for elective coronary artery bypass grafts (CABG) or single heart valve replacement who had a preoperative left ventricular ejection fraction (LVEF) estimated to be ≥50% and graded by the anesthesiologist in charge as ASA grade III. | Patients with age <18 years, pregnancy, coagulopathies or perforated viscus, esophageal or gastric abnormalities, nonpulsatile cardiopulmonary bypass, administration of aprotinin, and prior heart surgery or preexisting respiratory, hepatic, or renal disease.

NR Not Reported

Table D-2 Characteristics of Patients Receiving Cardiac Output Monitoring

Author/year | Year | Monitoring protocol | N | Age (mean ±SD) | % female | ASA grade | Goldman cardiac risk index | POSSUM score | Hemoglobin level at baseline (g/dl) | Type of surgery
Noblett et al.(42) | 2006 | EDM (CardioQ) + CVP + conventional protocol CVP + conventional protocol | 54 54 | 62.3 ± 14.0 67.6 ± 15.2 | NR NR | 2.1 ± 0.6 2.2 ± 0.6 | NR NR | 15.4 ± 4.2 16.1 ± 3.7 | NR NR | Elective bowel surgery (colorectal resection)
Wakeling et al.(43) | 2005 | EDM (CardioQ) + CVP + conventional protocol CVP + conventional protocol | 64 64 | 69.1 ± 12.3 69.6 ± 10.2 Median ± IQR | 40.6 46.9 | 2 ± 1 2 ± 1 Median ± IQR | NR NR | 17 ± 6.5 18 ± 7 Median ± IQR | NR NR | Elective or semi-elective bowel surgery
Conway et al.(44) | 2002 | EDM (Teco 2) + CVP + conventional protocol CVP + conventional protocol | 29 28 | 66.5 (12.5) 67.5 (10.1) | NR NR | I (I–III) II (I–III) Median (range) | 3 (3–11) 3 (3–29) Median (range) | NR NR | 12.8 (1.8) 12.8 (1.5) | Major non-emergent bowel surgery
Gan et al.(11) | 2002 | EDM (EDM^TM^ ) + CVP + conventional protocol CVP + conventional protocol | 50 50 | 56 (13) 59 (12) | 38 48 | II (I–III) II (I–III) Median (range) | NR NR | NR NR | 13.4 (1.9) 12.9 (1.7) | Major elective general, urologic, or gynecologic surgery
Venn et al.(46) | 2002 | EDM (CardioQ) + conventional protocol CVP + conventional protocol Conventional protocol | 30 31 29 | 82 (8.7) 85 (6.2) 84.5 (9.3) | 80 87.1 79.3 | 3 (2.5–3) 3 (3–4) 3 (3–4) Median (IQR) | NR NR NR | 35 (32–40) 40 (35–42) 38 (34–40) Median (IQR) | NR NR NR | Proximal femoral fracture repair
Sinclair et al.(47) | 1997 | EDM (ODM 2) + conventional protocol Conventional protocol | 20 20 | 74 (70.5–82) 75.5 (69–80) Median (IQR) | NR NR | 2 (2–3) 2 (2–3) Median (IQR) | 9 (9–13) 9 (8–12) Median (IQR) | NR NR | 12.5 (11.1–13.7) 12.7 (10.7–14) Median (IQR) | Proximal femoral fracture repair
Mythen and Webb(45) | 1995 | EDM (ODM 1) + CVP + conventional protocol CVP + conventional protocol | 30 30 | 63 (42–89) 64 (44–86) Mean (range) | NR NR | III III (All patients) | NR NR | NR NR | NR NR | Elective cardiac surgery (CABG or single valve replacement)

CVP Central Venous Pressure Monitoring

EDM Esophageal Doppler Monitoring

IQR Interquartile Range

NR Not Reported

Table D-3 Fluid Management Protocols in Studies Addressing Key Question 2

Reference | Year | Type of Surgery | Fluid management protocol for EDM group | Fluid management protocol for control group
Noblett et al.(42) | 2006 | Elective bowel surgery | In addition to routine fluid management, patients received colloid fluid boluses to maintain a descending aortic corrected flow time of > 0.35 seconds, and further boluses were given to optimize the stroke volume. Once achieved, further fluid boluses were given only if the stroke volume altered by >10% or the corrected flow time fell below 0.35 seconds. | Patients managed using routine fluid management at the discretion of the anesthiologist. Only some patients had CVP lines. All patients had EDM probes inserted, but they were not used to guide fluid administration according to a specific protocol. The anesthetist and those in charge of postoperative patient care were blinded to the EDM readings.
Wakeling et al.(43) | 2005 | Elective or semi-elective bowel surgery | In addition to routine fluid management, patients received 250 ml boluses of colloid solution. If stroke volume increased by 10% or more but CVP did not rise by 3 mm Hg or more, the fluid challenge was repeated. Fluid challenges were repeated until the stroke volume failed to rise by 10% and/or the CVP rose by 3 mm Hg or more. No further colloid fluid boluses were given until a 10% decrease in stroke volume occurred. Esophageal Doppler measurements were performed continuously. | Patients managed using routine cardiovascular monitoring and CVP measurements. CVP was used to guide i.v. fluid administration and was kept between 12 and 15 mm Hg. Anesthetist was blinded to esophageal Doppler measurements, which were taken before, after laparotomy, and at the end of the operation.
Conway et al.(44) | 2002 | Major non-emergent bowel surgery | In addition to routine fluid management, patients received additional colloid fluid boluses of 3 ml/kg according to an algorithm based on esophageal Doppler measurements. The algorithm was designed to optimize stroke volume (until SV did not increase by 10%) and maintain the corrected flow time >0.35 seconds. The anesthetist was blinded to EDM readings (but if the stroke volume fell in response to a fluid challenge and flow time and aortic velocity waveform indicated that the patient was volume overloaded, the anesthetist was unblinded). | Routine fluid management based on monitoring of heart rate, blood pressure, and (at the discretion of the anesthesiologist) CVP. EDM probe was inserted in all patients, and the anesthetist was blinded to EDM readings (but if the stroke volume fell in response to a fluid challenge and flow time and aortic velocity waveform indicated that the patient was volume overloaded, the anesthetist was unblinded).
Gan et al.(11) | 2002 | Major elective general, urologic, or gynecologic surgery | Patients received colloid fluid boluses of 200 ml according to an algorithm based on esophageal Doppler measurements. The algorithm was designed to optimize stroke volume (until SV did not increase by 10%) and maintain the corrected flow time >0.35 seconds. If the latter increased above 0.4 seconds with no change in stroke volume, further fluid was not administered until the stroke volume decreased by 10% of the last value. In addition, patients received fluid equivalent to that lost as a result of surgical hemorrhage. When 20 ml/kg of 6% hydroxyethy starch in saline had been given, lactated Ringer’s solution was used for further fluid boluses as required. Crystalloid was used in a 3:1 ratio for replacement of surgical blood loss. | The esophageal Doppler monitor was turned away from the anesthetist and the screen covered. Hemodynamic variables triggering fluid administration involved a urinary output <0.5 ml/kg/h, an increase in heart rate >20% above baseline or >110 beats/min, a decrease in mean systolic blood pressure <20% below baseline or <90 mm Hg, or CVP <20% of baseline. Boluses of 200 ml of fluid were administered until the above target was restored. The anesthesiologist would also administer additional fluid if deemed clinically indicated.
Venn et al.(46) | 2002 | Proximal femoral fracture repair | In addition to routine fluid management, patients received additional 200 ml colloid fluid challenges guided by Doppler measurements of stroke volume and corrected flow time. Similar to Conway et al. protocol, except if the corrected flow time rose above 0.4 seconds and the stroke volume remained the same, a further 100 ml colloid fluid was given. If after this fluid challenge the stroke volume still remained the same, no further fluid was given until the stroke volume fell by 10%. CVP was not recorded. | Control (no CVP) group: I.v. fluid administered as appropriate according to physician judgment (crystalloid and/or colloid). Although CVP was recorded, the clinician was blinded to measurements and unable to use them to guide therapy. No additional fluid boluses were given in this group. CVP group: in addition to routine fluid management, patients received additional 200 ml colloid fluid challenges guided by the response of CVP to a fluid challenge.
Sinclair et al.(47) | 1997 | Proximal femoral fracture repair | In addition to routine fluid management, patients received additional colloid fluid boluses of 3 ml/kg according to an algorithm based on esophageal Doppler measurements. The algorithm was designed to optimize stroke volume (until SV did not increase by 10%) and maintain the corrected flow time >0.35 seconds. If the latter increased above 0.4 seconds with no change in stroke volume, further fluid was not administered until the stroke volume decreased by 10% of the last value. CVP was not recorded. The anesthetist was blind to EDM readings, but aware of the fluid volumes given as fluid challenges to the protocol group. | Patients received crystalloid, colloid, or blood to replace estimated fluid losses and to maintain heart rate and blood pressure. CVP was not recorded. EDM probes were inserted in all patients, but the anesthetist was blinded to EDM readings.
Mythen and Webb(45) | 1995 | Elective cardiac surgery (CABG or single valve replacement) | In addition to routine fluid management, patients received additional 200 ml colloid fluid boluses to obtain a maximum stroke volume (when stroke volume failed to rise by 10%) and a rise in CVP >3 mm Hg. Stroke volume was monitored until a 10% decrease occurred, at which time another bolus was given. This procedure was repeated every 15 minutes until the end of surgery except when the patients underwent cardiopulmonary bypass. | Patients received crystalloid or colloid solutions based on judgment of the anesthetist. EDM probe was inserted in all patients, but operating room personnel were blinded to EDM readings.

CABG Coronary Artery Bypass Grafting

CVP Central Venous Pressure

EDM Esophageal Doppler Monitoring

Table D-4 Study Quality Evaluation – Studies Comparing Esophageal Doppler Monitoring Plus CVP Plus Conventional Protocol to CVP Plus Conventional Protocol

ECRI study quality scale - questions | Study
ECRI study quality scale - questions | Noblett et al. | Wakefield et al. | Conway et al. | Gan et al. | Mythen and Webb
1. Were patients randomly assigned to groups? | Yes | Yes | Yes | Yes | Yes
2. Did the study employ stochastic randomization? | Yes | NR | Yes | Yes | No
3. Were any methods used to make the groups comparable- randomization, matching, etc.? | Yes | Yes | Yes | Yes | Yes
4. Were patients assigned to groups based on factors other than patient or physician preference? | Yes | Yes | Yes | Yes | Yes
5. Were the characteristics of the patients in different groups comparable? | Yes | Yes | No | Yes | Yes
6. Did the patients in the different study groups have similar levels of performance on outcomes at baseline? | Yes | Yes | Yes | Yes | Yes
7. Was the study prospectively planned? | Yes | Yes | Yes | Yes | Yes
8. Did 85% or more of the patients complete the study? | Yes | Yes | Yes | Yes | Yes
9. Was there a less than 16% difference in completion rates in the study’s groups? | Yes | Yes | Yes | Yes | Yes
10. Were all of the study’s groups concurrently treated? | Yes | Yes | Yes | Yes | Yes
11. Was compliance with treatment greater than or equal to 85% in both of the groups? | Yes | Yes | Yes | Yes | Yes
12. Were both groups treated at the same centers? | Yes | Yes | Yes | Yes | Yes
13. Were subjects blinded to treatment? | Yes | Yes | Yes | Yes | Yes
14. Did the authors test and confirm that blinding of patients was maintained? | NR | NR | NR | NR | NR
15. Was the treating physician blinded to group assignment? | Yes | No | No | No | No
16. Were the outcome assessors blinded to group assignment? | Yes | Yes | No | Yes | Yes
17. Was there concealment of allocation? | Yes | Yes | Yes | Yes | Yes
18. Was the outcome of interest objective and was it objectively measured?^a^ | Yes | Yes | Yes | Yes | Yes
19. Were the same methods used to measure outcomes in all of the study’s groups?^a^ | Yes | Yes | Yes | Yes | Yes
20. Was the instrument used to measure the outcome standard?^a^ | Yes | Yes | Yes | Yes | Yes
21. Was the same treatment given to all of the patients enrolled in the experimental group? | Yes | Yes | Yes | No | Yes
22. Was the same treatment given to all of the patients enrolled in the control group? | Yes | Yes | Yes | No | Yes
23. Were the follow-up times in all of the study’s relevant groups approximately equal? | Yes | Yes | Yes | Yes | Yes
24. Was the funding for this study derived from a source that does not have a financial interest in its results? | Yes | Yes | Yes | No | Yes
25. Were the author’s conclusions supported by the data in the results section? | Yes | Yes | Yes | Yes | Yes
Quality score | 9.7 | 9.0 | 8.5 | 8.1 | 8.9
Quality rating | High | High | High | Moderate | High

Table D-5 Study Quality Evaluation – Studies Comparing Esophageal Doppler Monitoring Plus Conventional Protocol to Conventional Protocol

ECRI study quality scale - questions | Study
ECRI study quality scale - questions | Venn et al. | Sinclair et al.
1. Were patients randomly assigned to groups? | Yes | Yes
2. Did the study emply stochastic randomization? | Yes | No
3. Were any methods used to make the groups comparable- randomization, matching, etc.? | Yes | Yes
4. Were patients assigned to groups based on factors other than patient or physician preference? | Yes | Yes
5. Were the characteristics of the patients in different groups comparable? | NR | Yes
6. Did the patients in the different study groups have similar levels of performance on outcomes at baseline? | Yes | Yes
7. Was the study prospectively planned? | Yes | Yes
8. Did 85% or more of the patients complete the study? | Yes | Yes
9. Was there a less than 16% difference in completion rates in the study’s groups? | Yes | Yes
10. Were all of the study’s groups concurrently treated? | Yes | Yes
11. Was compliance with treatment greater than or equal to 85% in both of the groups? | Yes | Yes
12. Were both groups treated at the same centers? | Yes | Yes
13. Were subjects blinded to treatment? | Yes | Yes
14. Did the authors test and confirm that blinding of patients was maintained? | NR | NR
15. Was the treating physician blinded to group assignment? | No | No
16. Were the outcome assessors blinded to group assignment? | Yes | Yes
17. Was there concealment of allocation? | Yes | Yes
18. Was the outcome of interest objective and was it objectively measured?^a^ | Yes | Yes
19. Were the same methods used to measure outcomes in all of the study’s groups?^a^ | Yes | Yes
20. Was the instrument used to measure the outcome standard?^a^ | Yes | Yes
21. Was the same treatment given to all of the patients enrolled in the experimental group? | Yes | Yes
22. Was the same treatment given to all of the patients enrolled in the control group? | Yes | Yes
23. Were the follow-up times in all of the study’s relevant groups approximately equal? | Yes | Yes
24. Was the funding for this study derived from a source that does not have a financial interest in its results? | Yes | Yes
25. Were the author’s conclusions supported by the data in the results section? | Yes | Yes
Quality score | 9.0 | 8.9
Quality rating | High | High

Table D-6 Specific Complications Reported in Included Studies

Reference | Year | Type of Surgery | Reported complications
Trials comparing EDM + CVP + conventional protocol to CVP + conventional protocol
Noblett et al.(42) | 2006 | Elective bowel surgery | [underlined: Major complications]: Life-threatening complications requiring HDU or ICU care. Included death, pneumonia plus multiple organ dysfunction syndrome (MODS), anastomotic breakdown and MODS, sepsis and intra-abdominal collection, pneumonia requiring non-invasive ventilatory support. [underlined: Intermediate complications]: Complications requiring surgical, endoscopic, or radiological intervention. (Note: The authors reported the total number of intermediate or major complications for each treatment group.) [underlined: Other complications]: complications requiring pharmacological treatment, or deviations from normal postoperative course not requiring intervention. Specific complications mentioned were ileus, nausea, and vomiting.
Wakeling et al.(43) | 2005 | Elective or semi-elective bowel surgery | Death, pulmonary/thrombotic, infectious, renal, gastrointestinal, cardiovascular, neurological, wound, hemotological, pain, social. They did not separate major complications from total complications.
Conway et al.(44) | 2002 | Major bowel resections | Death, chest infection, pulmonary embolus, cardiac failure, arrhythmias, surgical problems requiring reoperation, delirium [underlined: Major complications]: complications requiring critical care. (Note: the authors did not report how many patients in each group had each type of complication, they only reported the total number of patients with complications in each group.)
Gan et al.(11) | 2002 | Major elective general, urologic, or gynecologic surgery with an anticipated blood loss of >500 ml. | Acute renal dysfunction, cardiovascular (hypotension, pulmonary edema, arrhythmia), chest infection, wound infection, coagulopathy, severe nausea/vomiting requiring emetic, respiratory support > 24 h. (Note: authors reported each of these complications separately for each treatment group. They did not report the total number of patients who had complications, they reported only the total number of events.)
Mythen and Webb(45) | 1995 | Elective coronary artery bypass grafts (CABG) or single heart valve replacement | [underlined: Major complications]: Death, multiple organ failure, chest infection with pleural effusion and disorientation, respiratory failure with nausea and vomiting, cerebrovascular accident, paralytic ileus with pericardial effusion and disorientation. [underlined: Minor complications]: wound infection, dyspnea, disorientation, persistent nausea and vomiting beyond third post-operative day. (Note: the authors only reported the number of patients who had major complications. Because they did not even report the number of minor complications, no estimate of total complications was possible).
Trials comparing EDM + conventional protocol to conventional protocol
Venn et al.(46) | 2002 | Hip fracture repair | Mortality, myocardial infarction, cardiac failure, rapid atrial fibrillation, hypotension, impaired renal function, pseudo-obstruction, chest infection, wound infection, urinary tract infection, cellulitis, pancreatitis, pulmonary embolus, deep hemorrhage requiring transfusion, hematemesis. (Note: authors reported each of these complications separately for each treatment group. They did not report the total number of patients who had complications, they reported only the total number of events.)
Sinclair et al.(47) | 1997 | Hip fracture repair | NR

HDU High dependency unit

ICU Intensive care unit

NR Not reported

Table D-7 Results for Key Question 2 - Mortality

Study | N | % operative deaths (n/N) | | | % post-operative deaths (in-hospital or within 30 days) (n/N) | | | % total deaths during trial (n/N)
Study | N | EDM group | Control group | p-value | EDM group | Control group | p-value | EDM group | Control group | p-value
Trials comparing EDM + CVP + conventional protocol to CVP + conventional protocol
Noblett et al.(42) | 103 | 0 (0/51) | 0 (0/52) | 1.0 | 0 (0/51) | 1.9 (1/52) | 1.0 | 0 (0/51) | 1.9 (1/52) | 1.0
Wakeling et al.(43) | 128 | 0 (0/64) | 0 (0/64) | 1.0 | 0 (0/64) | 0 (0/64) | 1.0 | 0 (0/64) | 1.6 (1/64) | 1.0
Conway et al.(44) | 57 | 0 (0/29) | 0 (0/28) | 1.0 | 0 (0/29) | 3.6 (1/28) | 0.49 | 0 (0/29) | 3.6 (1/28) | 0.49
Gan et al.(11) | 100 | 0 (0/50) | 0 (0/50) | 1.0 | 0 (0/50) | 0 (0/50) | 1.0 | 0 (0/50) | 0 (0/50) | 1.0
Mythen and Webb(45) | 60 | 0 (0/30) | 0 (0/30) | 1.0 | 0 (0/30) | 3.3 (1/30) | 1.0 | 0 (0/30) | 3.3 (1/30) | 1.0
Trials comparing EDM + conventional protocol to CVP + conventional protocol
Venn et al.(46) | 90 | 0 (0/30) | 0 (0/31) | 1.0 | 10 (3/30) | 19.4 (6/31) | 0.30 | 10 (3/30) | 19.4 (6/31) | 0.30
Trials comparing EDM + conventional protocol to conventional protocol
Venn et al.(46) | 90 | 0 (0/30) | 0 (0/29) | 1.0 | 10 (3/30) | 6.9 (2/29) | 1.0 | 10 (3/30) | 6.9 (2/29) | 1.0
Sinclair et al.(47) | 40 | 0 (0/20) | 0 (0/20) | 1.0 | 0 (0/20) | 5.0 (1/20) | 1.0 | 5.0 (1/20) | 10 (2/20) | 1.0

Table D-8 Results for Key Question 2 – Major Complications

Study | N | % major (life-threatening) complications during trial (n/N) | | Peto odds ratio (95% CI)^a^ | p-value^a^
Study | N | EDM group | Control group | Peto odds ratio (95% CI)^a^ | p-value^a^
Trials comparing EDM + CVP + conventional protocol to CVP + conventional protocol
Noblett et al.(42) | 103 | 0 (0/51) | 11.5 (6/52) | 0.13 (0.02 to 0.64) | 0.01
Conway et al.(44) | 57 | 0 (0/29) | 17.9 (5/28) | 0.11 (0.02 to 0.69) | 0.02
Mythen and Webb(45) | 60 | 0 (0/30) | 20 (6/30) | 0.11 (0.02 to 0.60) | 0.01

a Calculated by ECRI

Table D-9 Results for Key Question 2 – Total Complications

Study | N | % total complications during trial (n/N) | | Odds ratio (95% CI)^a^ | p-value^a^
Study | N | EDM group | Control group | Odds ratio (95% CI)^a^ | p-value^a^
Trials comparing EDM + CVP + conventional protocol to CVP + conventional protocol
Noblett et al.(42) | 103 | 25.5 (13/51) | 42.3 (22/52) | 0.47 (0.20 to 1.07) | 0.07
Wakeling et al.(43) | 128 | 37.5 (24/64) | 59.4 (38/64) | 0.41 (0.20 to 0.84) | 0.01
Conway et al.(44) | 57 | 17.2 (5/29) | 32.1 (9/28) | 0.44 (0.13 to 1.54) | 0.23
Gan et al.(11) | 100 | 42 (21/50)^b^ | 76 (38/50)^b^ | 0.23 (0.10 to 0.54) | 0.001
Trials comparing EDM + conventional protocol to CVP + conventional protocol
Venn et al.(46) | 90 | 33.3 (10/30) 46.7 (14/30)^b^ | 45.2 (14/31) 51.6 (16/31)^b^ | 0.61 (0.21 to 1.72) 0.82 (0.30 to 2.25) | 0.35 0.70
Trials comparing EDM + conventional protocol to conventional protocol
Venn et al.(46) | 90 | 33.3 (10/30) 46.7 (14/30)^b^ | 55.2 (16/29) 79.3 (23/29)^b^ | 0.41 (0.14 to 1.16) 0.23 (0.07 to 0.72) | 0.09 0.01
Sinclair et al.(47) | 40 | NR | NR

a Calculated by ECRI

b Total number of complications, not number of patients with complications

NR Not Reported

Table D-10 Results for Key Question 2 – Length of Hospital Stay

Study | N | Length of hospital stay (days)
Study | N | EDM group | Control group | p-value
Trials comparing EDM + CVP + conventional protocol to CVP + conventional protocol
Noblett et al.(42) | 103 | Median: 7 (IQR: 3 to 35) | Median: 9 (IQR: 4 to 45) | 0.005
Wakeling et al.(43) | 128 | Median: 10 (IQR: 5.75) | Median: 11.5 (IQR: 4.75) | 0.03
Conway et al.(44) | 57 | Mean: 18.7 (±20.2) Median: 12 (Range: 7 to 103) | Mean: 12.7 (±6.0) Median: 11 (Range: 7 to 30) | NR
Gan et al.(11) | 100 | Mean: 5 (±3) Median: 6 | Mean: 7 (±3) Median: 7 | 0.03 (for medians)
Mythen and Webb(45) | 60 | Mean: 6.4 (Range: 5 to 9) | Mean: 10.1 (Range: 5 to 48) | 0.01
Trials comparing EDM + conventional protocol to CVP + conventional protocol
Venn et al.(46) | 90 | Mean: 13.5 (95% CI: 10.9 to 17.5) | Mean: 13.3 (95% CI: 10.3 to 19.2) | 0.96
Trials comparing EDM + conventional protocol to conventional protocol
Venn et al.(46) | 90 | Mean: 13.5 (95% CI: 10.9 to 17.5) | Mean: 17.5 (95% CI: 13.9 to 24.4) | 0.31
Sinclair et al.(47) | 40 | Median: 11 (Range: 3 to 23) | Median: 20 (Range: 5 to 220) | <0.05

Table D-11 Meta-analysis – Length of Hospital Stay

(EDM + Conventional Protocol vs. Conventional Protocol)

Study | N = | Effect Size (days) | Lower 95% CI | Upper 95% CI | p-value | I^2^
Venn et al.(46) | 90 | −4.00 | −11.57 | 3.57 | 0.30 | NA
Sinclair et al.(47) | 40 | −9.00 | −15.83 | −2.17 | 0.01 | NA
Random-effects summary effect size | 130 | −6.76 | −11.83 | −1.68 | 0.009 | NA

Table D-12 Results of Sensitivity Analyses for Major Complications

(EDM + CVP + Conventional Protocol vs. CVP + Conventional Protocol)

Sensitivity analysis | Summary Peto log odds ratio (95% CI) | p value
Qualitative robustness
Removal of Noblett et al.(42) (largest study) | −2.19 (−3.42 to −0.96) | 0.0005
Removal of Conway et al.(44) (smallest study) | −2.13 (−3.30 to −0.96) | 0.0004
Removal of Mythen and Webb(45) | −2.13 (−3.35 to −0.91) | 0.0006
Removal of Conway et al., Mythen and Webb (two smallest studies) | −2.08 (−3.72 to −0.44) | 0.01
Removal of Noblett et al., Mythen and Webb (two largest studies) | −2.19 (−3.86 to −0.51) | 0.01
Assumption of no effect in studies that did not separately report major complications (Wakeling et al., Gan et al.) | −1.11 (−2.17 to −0.05) | 0.04
Original random-effects meta-analysis | −2.15 (−3.14 to −1.17) | 0.00002
Original random-effects meta-analysis using a different metric (Cohen’s h) | −0.80 (−1.07 to −0.54) Note: ES is Cohen’s h, not lnOR | <0.0000001

Table D-13 Results of Sensitivity Analyses for Total Complications

(EDM + CVP + Conventional Protocol vs. CVP + Conventional Protocol)

Sensitivity analysis | Summary log odds ratio (95% CI) | p value
Quantitative and Qualitative robustness
Removal of Noblett et al.(42) (largest study) | −1.08 (−1.58 to −0.58) | 0.00003
Removal of Wakeling et al.(43) | −1.06 (−1.60 to −0.52) | 0.0001
Removal of Gan et al.(11) | −0.83 (−1.33 to −0.34) | 0.001
Removal of Conway et al.(44) (smallest study) | −1.02 (−1.48 to −0.56) | 0.00001
Removal of Conway et al., Gan et al. (two smallest studies) | −0.84 (−1.38 to −0.30) | 0.002
Removal of Noblett et al., Wakeling et al. (two largest studies) | −1.27 (−1.97 to −0.56) | 0.0005
Assumption of no effect in study that did not report total complications (Mythen and Webb) | −0.84 (−1.27 to −0.40) | 0.0002
Original random-effects meta-analysis | −1.00 (−1.43 to −0.57) | 0.000006
Original random-effects meta-analysis using a different metric (Cohen’s h) | −0.47 (−0.67 to −0.28) Note: ES is Cohen’s h, not lnOR | 0.000003

Table D-14 Results of Sensitivity Analyses for Length of Hospital Stay

(EDM + CVP + Conventional Protocol vs. CVP + Conventional Protocol)

Sensitivity analysis | Summary days (95% CI) | p value
Qualitative robustness
Removal of Noblett et al.(42) (largest study) | −1.32 (−2.18 to −0.45) | 0.003
Removal of Wakeling et al.(43) | −1.32 (−2.35 to −0.29) | 0.01
Removal of Gan et al.(11) | −1.75 (−2.89 to −0.60) | 0.003
Removal of Mythen and Webb(45) | −1.28 (−2.11 to −0.44) | 0.003
Removal of Conway et al.(44) (smallest study) | −1.40 (−2.23 to −0.58) | 0.0008
Removal of Noblett et al, Wakeling et al. (two largest studies) | −1.20 (−2.31 to −0.08) | 0.04
Removal of Conway et al., Mythen and Webb (two smallest studies) | −1.29 (−2.14 to −0.45) | 0.003
Original random-effects meta-analysis | −1.39 (−2.21 to −0.57) | 0.0009
Random-effects meta-analysis using only means when available | −1.80 (−2.84 to −0.76) | 0.0007
Random effects meta-analysis using more conservative assumptions about ranges and interquartile ranges | −1.29 (−2.30 to −0.27) | 0.01
Random effects meta-analysis using more conservative assumptions about ranges and interquartile ranges and assuming medians are equal in the study by Mythen and Webb (which only reported means and SDs) | −1.03 (−2.05 to −0.01) | 0.047
Random effects meta-analysis using a different metric (Hedges’ g) | −0.31 (−0.49 to −0.12) Note: ES is Hedges’ g, not days | 0.001