# Summary Evidence Tables

Table C-1 Summary of Included Studies (Key Questions 2 and 3)

Author/Year | Study Design/Purpose | Intervention/Outcomes | Demographics | Results
Noblett et al. 2006(42) | Design: RCT Purpose: to assess the effect of optimizing hemodynamic status, using a protocol-driven intraoperative fluid regimen, on outcome following elective colorectal resection. ECRI Quality Score (Rating): 9.1 (High) | Treatment Intervention: EDM (CardioQ) + CVP + conventional protocol Control Intervention: CVP + conventional protocol | Total Enrolled: 108 54 in treatment group 54 in control group Age (median ± IQR) Treatment: 62.3 ± 14.0 Control: 67.6 ± 15.2 % female: Treatment: NR Control: NR Type of surgery: Elective bowel surgery Inclusion Criteria: Patients requiring elective bowel surgery Exclusion Criteria: Severe esophageal disease, recent esophageal or upper airway surgery, systemic steroid medication, moderate or severe aortic valve disease, bleeding diathesis and patient choice. | Mortality: Treatment: 0% (0/51) Control: 1.9% (1/52) p-value: 1.0 Major complications: Treatment: 0% (0/30) Control: 11.5% (6/30) p-value: 0.01 Total complications: Treatment: 25.5% (13/51) Control: 42.3% (22/52) p-value: 0.07^a^ Length of hospital stay (median days) Treatment: 7 (IQR: 3 to 35) Control: 9 (IQR: 4 to 45) p-value: 0.005
Wakeling et al. 2005(43) | Design: RCT Purpose: to determine whether using intraoperative esophageal Doppler guided fluid management to minimize hypovolemia would reduce post-operative hospital stay and the time before return to gut function after colorectal surgery. ECRI Quality Score (Rating): 9.0 (High) | Treatment Intervention: EDM (CardioQ) + CVP + conventional protocol Control Intervention: CVP + conventional protocol | Total Enrolled: 128 64 in treatment group 64 in control group Age (median ± IQR) Treatment: 69.1 ± 12.3 Control: 69.6 ± 10.2 % female: Treatment: 40.6 Control: 46.9 Type of surgery: Elective or semi-elective bowel surgery Inclusion Criteria: Patients requiring elective or semi-elective bowel surgery Exclusion Criteria: Patients with age <18 years, hepatic pathology, perforated viscus, esophageal pathology, and coagulopathy | Mortality: Treatment: 0% (0/64) Control: 1.6% (1/64) p-value: 1.0 Major complications: Not reported separate from total complications Total complications: Treatment: 37.5% (24/64) Control: 59.4% (38/64) p-value: 0.01 Length of hospital stay (median days) Treatment: 10 (IQR 5.75) Control: 11.5 (IQR 4.75) p-value: 0.03
Conway et al. 2002(44) | Design: RCT Purpose: to examine the effect of esophageal Doppler guided fluid administration during colorectal resection on hemodynamic performance, hospital stay, and post-operative complications ECRI Quality Score (Rating): 8.5 (High) | Treatment Intervention: EDM (TECO 2) + CVP + conventional protocol Control Intervention: CVP + conventional protocol | Total Enrolled: 57 29 in treatment group 28 in control group Age (mean ± SD) Treatment: 66.5 ± 12.5 Control: 67.5 ± 10.1 % female: Treatment: NR Control: NR Type of surgery: Major non-emergent bowel surgery Inclusion Criteria: Patients undergoing major bowel resections Exclusion Criteria: Patients undergoing emergency, intrathoracic, or esophageal surgery, patients with known sensitivity to starch-based colloid or history of esophageal disease | Mortality Treatment: 0% (0/29) Control: 3.6% (1/28) p-value: 0.49 Major complications: Treatment: 0% (0/30) Control: 17.9% (5/30) p-value: 0.02 Total complications Treatment: 17.2% (5/29) Control: 32.1% (9/28) p-value: 0.23^a^ Length of hospital stay: Mean ±SD in days Treatment: 18.7 ±20.2 Control: 12.7 ±6.0 Median (range) Treatment: 12 (7–103) Control: 11 (7–30) p-value: NR
Gan et al. 2002(11) | Design: RCT Purpose: to investigate whether goal-directed intraoperative plasma volume expansion guided by the EDM would shorten the length of hospital stay and improve post-operative outcomes in patients undergoing moderate risk surgery ECRI Quality Score (Rating): 8.1 (Moderate) | Treatment Intervention: EDM (EDM^TM^) + CVP + conventional protocol Control Intervention: CVP + conventional protocol | Total Enrolled: 100 50 in treatment group 50 in control group Age (mean ± SD) Treatment: 56 ± 13 Control: 59 ± 12 % female: Treatment: 38 Control: 48 Type of surgery: Major elective general, urologic, or gynecologic surgery Inclusion Criteria: Patients with American Society of Anesthesiologists (ASA) physical status I, II, and III who were to undergo major elective general, urologic, or gynecologic surgery with an anticipated blood loss of >500 ml. Exclusion Criteria: Patients with age <18 years, emergency surgery, preoperative bowel obstruction, coagulopathy, significant renal and hepatic dysfunction (creatinine >50% or liver enzymes >50% upper limit of normal values), congestive heart failure, and esophageal pathology (avoid potential complications of the esophageal probe), and those undergoing gastric or esophageal surgery or who were on antiemetic medication within 3 days of surgery | Mortality: Treatment: 0% (0/50) Control: 0% (0/50) p-value: 1.0 Major complications: Not reported separate from total complications Total complications: Treatment: 42% (21/50) Control: 76% (38/50) p-value: 0.001^a^ Length of hospital stay: Mean ± SD in days Treatment: 5 ± 3 Control: 7 ± 3 Median Treatment: 6 Control: 7 p-value: 0.03
Venn et al. 2002(46) | Design: RCT Purpose: to investigate whether repeated colloid fluid challenges to optimize the circulation intraoperatively, guided by CVP or esophageal Doppler ultrasonography, would benefit high-risk patients admitted with fractured hips to a London teaching hospital ECRI Quality Score (Rating): 9.0 (High) | Treatment Intervention: EDM (CardioQ) + conventional protocol Control Intervention: CVP + conventional protocol Other Intervention: Conventional protocol alone | Total Enrolled: 90 30 in treatment group 31 in control group 29 in other group Age (mean ± SD) Treatment: 82 ± 8.7 Control: 85 ± 6.2 Other: 84.5 ± 9.3 % female: Treatment: 80 Control: 87.1 Other: 79.3 Type of surgery: Proximal femoral fracture repair Inclusion Criteria: Patients admitted with fractured hips Exclusion Criteria: Patients with age <65 years, esophageal pathology, central venous cannula already in situ, pathological fracture of femur, refusal of informed consent, and those undergoing regional anesthesia | Mortality: Treatment: 10% (3/30) Control: 19.4% (6/31) Other: 6.9% (2/29) p-value: 0.31 Major complications: Not reported separate from total complications Total complications: Treatment: 46.7% (14/30) Control: 51.6% (16/31) Other: 79.3% (23/29) p-value: 0.24 Length of hospital stay: Mean days (95% CI) Treatment: 13.5 (10.9 to 17.5) Control: 13.3 (10.3 to 19.2) Other: 17.5 (13.9 to 24.4) p-value: 0.035
Sinclair et al. 1997(47) | Design: RCT Purpose: to examine the possible benefits of intraoperative circulatory optimization using EDM in patients with fractured neck of femur ECRI Quality Score (Rating): 8.9 (High) | Treatment Intervention: EDM (ODM 2) + conventional protocol Control Intervention: Conventional protocol | Total Enrolled: 40 20 in treatment group 20 in control group Age (Median and IQR) Treatment: 74 (70.5–82) Control: 75.5 (69–80) % female: Treatment: NR Control: NR Type of surgery: Proximal femoral fracture repair Inclusion Criteria: Patients with fractures of the femoral neck of the hip Exclusion Criteria: Patients with age <55 years, fracture secondary to neoplasm, fractures occurring during hospitalization for an acute illness, fracture through the site of a previous surgical correction or associated with instabiliy of a previous prosthesis, planned regional anesthesia (precluding placement of Doppler probe), and refusal of consent or inability to contact next of kin in the case of patietns unable to give consent themselves | Mortality: Treatment: 5% (1/20) Control: 10% (2/20) p-value: 1.0 Major and Total complications: Treatment: NR Control: NR p-value: NR Length of hospital stay: Median and range in days: Treatment: 11 (3 to 23) Control: 20 (5 to 220) p-value: <0.05
Mythen and Webb 1995(45) | Design: RCT Purpose: to test the hypothesis that perioperative plasma volume expansion with colloid (guided by EDM + CVP) would maintain pHi during elective cardiac surgery ECRI Quality Score (Rating): 8.9 (High) | Treatment Intervention: EDM (ODM 1) + CVP + conventional protocol Control Intervention: CVP + conventional protocol | Total Enrolled: 60 30 in treatment group 30 in control group Age (mean and range) Treatment: 63 (42–89) Control: 64 (44–86) % female: Treatment: NR Control: NR Type of surgery: Elective cardiac surgery (CABG or single valve replacement) Inclusion Criteria: Patients scheduled for elective coronary artery bypass grafts (CABG) or single heart valve replacement) who had a preoperative left ventricular ejection fraction (LVEF) estimated to be ≥50% and graded by the anesthesiologist in charge as ASA grade III. Exclusion Criteria: Patients with age <18 years, pregnancy, coagulopathies or perforated viscus, esophageal or gastric abnormalities, nonpulsatile cardiopulmonary bypass, administration of aprotinin, and prior heart surgery or preexisting respiratory, hepatic, or renal disease. | Mortality: Treatment: 0% (0/30) Control: 3.3% (1/30) p-value: 1.0 Major complications: Treatment: 0% (0/30) Control: 20% (6/30) p-value: 0.01 Total complications: Treatment: NR Control: NR p-value: NR Length of hospital stay: Mean and range in days Treatment: 6.4 (5 to 9) Control: 10.1 (5 to 48) p-value: 0.01
McKendry et al. 2004(48) | Design: RCT Purpose: to assess whether a nurse led, flow monitored protocol for optimizing circulatory status in patients after cardiac surgery reduces complications and shortens stay in intensive care and hospital ECRI Quality Score (Rating): 8.5 (High) | Treatment Intervention: EDM (CardioQ) + conventional protocol Control Intervention: Conventional protocol | Total Enrolled: 174 89 in treatment group 85 in control group Age (mean ± SD) Treatment: 65.6 ± 10.3 Control: 66.7 ± 10.2 % female: Treatment: 37 Control: 33 Type of surgery: Cardiopulmonary bypass surgery Inclusion Criteria: Patients undergoing cardiopulmonary bypass surgery who had provided informed consent Exclusion Criteria: Patients with age <18 years, those undergoing off-pump surgery, those who declined consent, or those with relative contraindications to use of the esophageal Doppler probe (esophageal varices or other oropharyngeal and esophageal disease). | Mortality: Treatment: 4.5% (4/89) Control: 2.4% (2/85) p-value: 0.68 Major complications: Not reported separate from total complications Total complications: Treatment: 19.1% (17/89) Control: 30.6% (26/85) p-value: 0.08^a^ Length of hospital stay: Mean days: Treatment: 11.4 Control: 13.9 p-value: NR Median days: Treatment: 7 Control: 9 p-value: 0.02

a Calculated by ECRI