# Quality of Literature and Evidence Strength Rating

## Study Quality Scale

A poorly designed study may contain biases that may make a treatment look more or less effective than it actually is. In well-designed studies, the outcomes can be definitively attributed to the treatment of interest.

In order to grade the quality of studies, we use a quality rating scale. This scale allows us to calculate an evidence quality score based on a priori quality criteria. The questions in the scale are worded so that study design aspects that provide evidence with good internal validity result in “Yes” answers, design aspects that create potential for bias result in “No”, and design aspects that are inadequately described result in an answer of “NR” (not reported).

The 25-item quality assessment instrument used to assess the quality of the three studies that addressed Key Question 3 is presented below:

Comparability of Groups at Baseline
1. Were patients randomly assigned to the study’s groups?
2. Did the study employ stochastic randomization?
3. Were any methods other than randomization used to make the patients in the study’s groups comparable?
4. Were patients assigned to groups based on factors other than patient or physician preference?
5. Were the characteristics of patients in the different study groups comparable at the time they were assigned to groups?
6. Did patients in the different study groups have similar levels of performance on all of the outcome variables at the time they were assigned to groups?
7. Was the comparison of interest prospectively planned?
8. Did ≥85% of the patients compete they study?
9. Was there a ≤15% difference in completion rates in the study’s groups?
10. Were all of the study’s groups concurrently treated?
11. Was compliance with treatment ≥85% in both of the study’s groups?
12. Was there concealment of allocation?

Blinding
13 Were subjects blinded to the treatment they received?
14 Did the authors perform any tests after completing the study to ensure that the integrity of the blinding of patients was maintained throughout the study?
15 Was the treating physician blinded to the groups to which the patients were assigned?
16 Were those who assessed the patient’s outcomes blinded to the group to which the patients were assigned?

Measurement/Instrument
17 Was the outcome measure of interest objective and was it objectively measured?
18 Were the same laboratory tests, clinical findings, psychological instruments, etc., used to measure the outcomes in all of the study’s groups?
19 Was the instrument used to measure the outcome standard?
20 Were the follow-up times in all of the study’s relevant groups approximately equal?

Treatment
21 Was the same treatment given to all patients enrolled in the experimental group?
22 Was the same treatment given to all patients enrolled in the control group?
23 Were all of the study’s groups treated at the same center?

Investigator Bias
24 Was the funding for this study derived from a source that does not have a financial interest in its results?
25 Were the author’s conclusions, as stated in the abstract or the article’s discussion section, supported by the data presented in the article’s results section?

We used these items to compute a summary score, which ranges from 0 to 10, where 10 indicates an ideal study and 0 indicates a study of the poorest possible quality. To compute this summary score, we made the following calculations. We first converted the individual item answers to numeric scores by counting 1 for each Yes answer, −1 for each No, and −0.5 for each NR. We then added the numeric scores for all 25 items, added 25 to the total, divided by 50, and multiplied by 10. These calculations yield the 0–10 summary scale described above. Studies that scored less than 5 were considered unacceptable quality, greater than 5 but less than or equal to 6.7 were considered low quality, greater than 6.7 but less than or equal to 8.4 were considered moderate quality, and 8.5 or greater were considered high quality.

## Strength of Evidence Algorithm

After grading the body of evidence for a particular question on each of several decision points (listed in the next sections), we apply the grades to an algorithm that divides the strength of the evidence supporting each conclusion into one of four categories: strong, moderate, weak, or inconclusive. Table B-1 illustrates how these categories relate to qualitative and quantitative conclusions.

Table B-1 Interpretation of Different Categories of Strength of Evidence Supporting Conclusion

Strength of Evidence | Interpretation of Qualitative Conclusion
Strong | Evidence supporting the qualitative conclusion is convincing. It is highly unlikely that new evidence will lead to a change in this conclusion.
Moderate | Evidence supporting the qualitative conclusion is somewhat convincing. There is a small chance that new evidence will overturn or strengthen our conclusion. ECRI recommends regular monitoring of the relevant literature at this time.
Weak | Although some evidence exists to support the qualitative conclusion, this evidence is tentative and perishable. There is a reasonable chance that new evidence will overturn or strengthen our conclusions. ECRI recommends frequent monitoring of the relevant literature at this time.
Inconclusive | Although some evidence exists, this evidence is not of sufficient strength to warrant drawing an evidence-based conclusion from it. ECRI recommends frequent monitoring of the relevant literature at this time.
Stability of Evidence | Interpretation of Quantitative Conclusion
High | The estimate of treatment effect included in the conclusion is stable. It is highly unlikely that the magnitude of this estimate will change substantially as a result of the publication of new evidence.
Moderate | The estimate of treatment effect included in the conclusion is somewhat stable. There is a small chance that the magnitude of this estimate will change substantially as a result of the publication of new evidence. ECRI recommends regular monitoring of the relevant literature at this time.
Low | The estimate of treatment effect included in the conclusion is likely to be unstable. There is a reasonable chance that the magnitude of this estimate will change substantially as a result of the publication of new evidence. ECRI recommends frequent monitoring of the relevant literature at this time.
Inconclusive | Estimates of the treatment effect are too unstable to allow a quantitative conclusion to be drawn at this time. ECRI recommends frequent monitoring of the relevant literature.

To arrive at these strength-of-evidence categories, we applied the ECRI Strength of Evidence Algorithm. This algorithm, which appears in Figure 3 through Figure 6 below, involves 10 decision points. The methods we used to resolve these 10 decision points appear next.

Figure 3 General Section of Strength-of-Evidence Algorithm

Figure 3. General Section of Strength-of-Evidence Algorithm

Figure 4 High Quality Arm of Strength-of-Evidence Algorithm

Figure 4. High Quality Arm of Strength-of-Evidence Algorithm

Figure 5 Moderate Quality Arm of Strength-of-Evidence Algorithm

Figure 5. Moderate Quality Arm of Strength-of-Evidence Algorithm

Figure 6 Low Quality Arm of Strength-of-Evidence Algorithm

Figure 6. Low Quality Arm of Strength-of-Evidence Algorithm

### Decision Point #1 Acceptable quality

The above section entitled Study Quality Scale describes our approach to determining whether each study was of acceptable quality.

### Decision Point #2 Overall quality

After assigning quality scores to each individual study, we then classified the overall quality of the evidence base by taking the median of the Overall quality scores. Quality scores were converted to categories as defined in Table B-2. For example, if the evidence base consists of four studies with overall scores of 6.5, 7, 7.8, and 9, then the median is 7.4 and the overall evidence base is considered moderate quality. The definitions for what constitutes low, moderate, or high quality evidence were determined a priori by a committee of three methodologists. If the median quality was on the border between categories, we took the lower quality category as the overall quality.

Table B-2 Categorization of Quality

| High quality | Moderate quality | Low quality
Median quality | >8.4 | >6.7 but ≤8.4 | >5 but ≤6.7

### Decision Point #3 Does Reporting Allow Quantitative Analysis to be Performed?

The answer to Decision Point 3 depends upon the adequacy of reporting in available studies as well as the number of available studies. In order to conduct a quantitative analysis of a given outcome, the data for that outcome must be reported in at least three studies in a manner that allows the data to be pooled in a meta-analysis. If less than three studies are available, no quantitative conclusion is usually possible regardless of reporting. Another situation that does not allow a quantitative conclusion is when three or more studies are available, but fewer than 80% of them permit determination of the effect size and its dispersion, either by direct reporting from the trial or calculations based on reported information. Finally, no quantitative conclusion is possible if fewer than 80% of available studies report a given outcome. If no quantitative conclusion is possible, then one moves directly to Decision Point 8 to begin a qualitative analysis.

### Decision Point #4 Are Data Quantitatively Consistent (Homogeneous)?

This decision point is used only if the answer to Decision Point 3 was Yes. Consistency refers to the extent to which the results of studies in an evidence base agree with each other.(66) The more consistent the evidence, the more precise a summary estimate of treatment effect derived from the evidence base. Quantitative consistency refers to consistency tested in a meta-analysis using the Q statistic and Higgins and Thompson’s I^2^ statistic.(28) We consider the evidence base to be quantitatively consistent when I^2^ <50% and the p-value of Q is ≥0.10 (both criteria must be met).

If the studies are homogeneous, we combine the results in a fixed-effects meta-analysis (FEMA). We then determine whether the summary effect size is informative or non-informative. The summary effect is considered informative if it meets any one of the following three criteria:

1. The summary effect is statistically significant.
2. If the minimum boundary of clinical significance is greater than 0, the 95% confidence intervals of the summary effect must exclude the possibility of a clinically significant effect.
3. If the boundary of clinical significance equals 0 (clinical significance = statistical significance), the 95% confidence intervals of the summary effect must not overlap with −0.2 or +0.2 (this assumes one is using Hedges’ d or Cohen’s h as the meta-analytic summary statistic; for the log odds ratio, the interval is −0.4 to +0.4).

Criteria 2) and 3) require definitions of the minimum difference between treatments (or between baseline and post-treatment measurements) that is considered clinically significant. The definitions that we used appear in Table B-3.

Table B-3 Definitions of clinical significance

Outcome | Minimum effect considered to be clinically significant
Key Question 2
Complications (including mortality) | Any statistically significant difference
Hospital stay | 1 day (difference between treatment groups)
Key Question 3
Complications (including mortality) | Any statistically significant difference
Hospital stay | 1 day (difference between treatment groups)

We did not identify any clinical consensus in the literature regarding what constitutes a clinically significant difference in the length of hospital stay (either as an absolute number of days or as a fraction of the expected length of stay). Therefore, our choice of one day as the minimum clinically significant difference for hospital stay is subjective. Our assumption is that if the average duration of stay is less than two weeks, a difference of at least one day would be important to patients. Also, every additional day a patient stays in a hospital increases their risk of acquiring a nosocomial infection. However, other reviewers might consider a shorter or longer difference in length of stay to be clinically significant.

If the summary effect is informative, we then test the stability of the findings in decision point 5.

### Decision Point #5 Are Findings Stable (Quantitatively Robust)?

Stability of findings refers to the likelihood that a summary effect estimate will be substantially altered by changing the conditions of the analysis. This was tested by first removing each individual study separately to see if any single study had a substantial influence on the summary result. Secondly we performed cumulative meta-analysis.

A pre-requisite of an analysis of quantitative robustness is that the 95% confidence interval around a meta-analytic effect size should not exceed a certain range. If the difference between the upper and lower bounds is GREATER than 0.4, then the estimate is automatically considered not robust (no analysis necessary). If it is less than or equal to 0.4, then perform an analysis of quantitative robustness. This number (0.4) is based on the use of 0.2 as the minimum clinically important effect. Thus, if the confidence interval width is less than 0.4, then the point estimate must be within 1 unit of clinical significance, which would pass this initial pre-requisite. This number also assumes that one is using either Hedges’ d or Cohen’s h as the measure of effect size. If a different effect size measure is being used, one would change the number accordingly. When using the log odds ratio, the interval becomes 0.8. We refer to the point estimate of the meta-analytic summary statistic as SES_full_.

1. Compute SES_full_ +0.2 and SES_full_ −0.2. These will denote the two horizontal dashed lines in your cumulative meta-analysis plot, to represent the range of acceptable deviation from SES_full._
2. Determine which study had the lowest weight in the meta-analysis (usually this will be the smallest study). Remove that study, and recompute the SES and its confidence bounds.
3. If EITHER the upper bound is greater than SES_full_ +0.2, OR the lower bound is less than SES_full_ −0.2, then the estimate is not robust. On the plot, this is equivalent to whether the CI crosses EITHER dashed line. If neither line is crossed, continue to the next step.
4. Determine which study had the next lowest weight in the meta-analysis (usually this will be the next-to-smallest study). Remove that study also, and recompute the SES and its confidence bounds. This meta-analysis is based on k-2 studies.
5. If EITHER the upper bound is greater than SES_full_ +0.2, OR the lower bound is less than SES_full_ −0.2, then the estimate is not robust. On the plot, this is equivalent to whether the CI crosses EITHER dashed line.
6. If EITHER of the above meta-analyses changes the summary effect estimate by ≥ 10%, then the estimate is not robust.
7. If EITHER of the above meta-analyses shows significant heterogeneity (either an I^2^≥50% or a Q with a p-value <0.10), then the estimate is not robust.

### Decision Point #6 Meta-regression Explains Heterogeneity?

Meta-analyses with heterogeneity are further evaluated with meta-regression. Meta-regression is not performed on a low quality evidence base. Heterogeneity was assessed by meta-regression using the permutation test method of Higgins and Thompson (2004)(67) and the meta-regression module in the Stata software package.(68) Meta-regression was only performed if there were 10 or more studies in an evidence base with an average quality that was moderate or high, and if ≥80% of the studies had data allowing effect sizes to be calculated without imputation.(69) Because none of the evidence bases evaluated in this report had 10 or more studies, meta-regression could not be performed.

### Decision Point #7 Meta-regression Model Robust?

If heterogeneity can be explained with meta-regression does the model hold through sensitivity testing? Testing would involve removal of each individual study from the meta-regression to determine whether removal of any single study changes the results of the meta-regression. However, no meta-regressions were performed in this report.

### Decision Point #8 Qualitatively Robust?

If the evidence base for an outcome had three or more studies, we determined whether the qualitative findings could be overturned by removal of any single study, changing the measure of effect, or cumulative meta-analysis. We considered findings to be overturned only when a study removal altered the conclusion (i.e., a statistically significant finding becomes non-significant as studies are added to the evidence base). However, the analysis differs somewhat depending upon which of the following four bolded questions is being addressed.

#### Is the qualitative finding that the effect size is different from 0 robust?

The steps below are taken only if the all-study summary SES is statistically significant, because if it were not, then one must be testing the conclusion that there is no clinically significant difference, which is addressed in the 4^th^ bolded question below.

1. Compute the meta-analysis based on the separate removal of each of the studies (if there are four studies, this will be four separate meta-analyses). If all of the meta-analyses are statistically significant in the same direction as the full MA, then the conclusion is qualitatively robust.
2. Compute the meta-analysis based on the cumulative removal of studies (the last two from smallest to largest and from largest to smallest). If all of the meta-analyses are statistically significant in the same direction as the full MA, then the conclusion is qualitatively robust.

#### Is the qualitative finding that the effect size is clinically significant robust?

The steps below are taken only if the all-study summary SES lies fully above the line of clinical significance (i.e., the lower bound of the CI is greater than the line of clinical significance).

1. Compute the meta-analysis based on the separate removal of each of the studies. If the lower bound of the SES is above the line of clinical significance for each meta-analysis, then the conclusion is qualitatively robust.
2. Compute the meta-analysis based on the cumulative removal of studies (the last two from smallest to largest and from largest to smallest). If the lower bound of the SES is above the line of clinical significance for each meta-analysis, then the conclusion is qualitatively robust.

#### Is the qualitative finding that the effect size is not clinically significant robust?

The steps below are taken only if the all-study summary SES lies fully below the line of clinical significance (i.e., the upper bound of the CI is lower than the line of clinical significance).

1. Compute the meta-analysis based on the separate removal of each of the studies. If the upper bound of the SES is below the line of clinical significance, then the conclusion is qualitatively robust.
2. Compute the meta-analysis based on the cumulative removal of studies (the last two from smallest to largest and from largest to smallest). If the upper bound of the SES is below the line of clinical significance, then the conclusion is qualitatively robust.

#### Is the qualitative finding that the effect size is not substantial robust?

The steps below are taken only if the cutoff for clinical significance is identical to the cutoff for statistical significance (zero) and if the confidence intervals around the all-study summary SES overlap with zero. This cutoff for clinical significance is generally used for severe adverse events (for example, when the outcome is death, even a miniscule difference is clinically important, thus zero is taken as the cutoff for clinical significance). Note: for this bolded question, if the upper or lower bound of the SES overlaps with −0.2 or 0.2 (again assuming the effect size measure is Hedges’ d or Cohen’s h; for the log odds ratio, the interval is −0.4 to 0.4), then no qualitative conclusion is possible (the evidence base is inconclusive). Otherwise, follow the steps below.

1. Compute the meta-analysis based on the separate removal of each of the studies. If the upper or lower bound of the SES still overlaps zero and both are between −0.2 and 0.2, then it is robust.
2. Compute the meta-analysis based on the cumulative removal of studies (the last two from smallest to largest and from largest to smallest). If the upper or lower bound of the SES still overlaps zero and both are between −0.2 and 0.2, then it is robust.

### Decision Point #9 Qualitatively Consistent?

This Decision Point is used only when the evidence base for an outcome consists of two studies. For a given outcome, studies were considered qualitatively consistent if both studies had a statistically significant effect in the same direction, or if both studies did not have a statistically significant effect.

### Decision Point #10 Magnitude of Effect Extremely Large?

When considering the strength of evidence supporting a qualitative conclusion based on only one or two studies, magnitude of effect becomes very important. If a single study finds a large effect with a narrow confidence interval, then new evidence is unlikely to overturn the qualitative conclusion. To resolve this decision point, we consulted the effect size and the 95% confidence interval around the effect size for the study (with two studies, we consulted the interval around the random effects summary statistic). If this interval was fully above +0.5 (or if it was fully below −0.5) and the effect size was ≥0.8 (or ≤−0.8), we considered the effect to be large. Otherwise, we considered it to be not large. For example, an interval from +0.6 to +1.1 would be considered a large effect, whereas an interval from +0.4 to +1.3 would not be considered a large effect. Another effect that would be considered large is an interval from −1.1 to −0.6 (large in the negative direction). The choice of 0.5 and 0.8 is based on Cohen,(70) who stated that an effect size of 0.5 was “moderate” and 0.8 was “large”; thus the decision rule required that the effect be statistically significantly larger than “moderate”. The use of 0.5 and 0.8 applies to both Hedges’ d and Cohen’s h as measures of effect size. When using the log odds ratio, small, moderate, and large effects are 0.4, 0.9, and 1.5, respectively. For length of hospital stay, we judged small, moderate, and large effects to be 1 day, 2 days, and 3 days, respectively.