# Literature Searches

## Electronic Database Searches

To obtain information for this report, we searched the following databases for relevant information:

Database | Date limits | Platform/provider
CINAHL (Cumulative Index to Nursing and Allied Health Literature) | 1982 through September 11, 2006 | OVID
The Cochrane Central Register of Controlled Trials (CENTRAL) | Inception through 2006, Issue 3 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Inception through 2006, Issue 3 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Inception through 2006, Issue 3 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Inception through 2006, Issue 3 | www.thecochranelibrary.com
ECRI Health Devices Alerts | 1977 through June 7, 2006 | ECRI
ECRI International Health Technology Assessment (IHTA) | Inception through June 7, 2006 | ECRI
ECRI Library Catalog | Inception through March 2006 | ECRI
Embase (Excerpta Medica) | 1974 through September 11, 2006 | OVID
Health Technology Assessment Database (HTA) | Inception through 2006, Issue 3 | www.thecochranelibrary.com
MEDLINE | 1966 through September 11, 2006 | OVID
metaRegister of Controlled Trials (mRCT) | Searched June 14, 2006 | http://www.controlled-trials.com/mrct/
PubMed (PreMEDLINE, Publisher) | Through September 11, 2006 | www.pubmed.gov
U.K. National Health Service Economic Evaluation Database (NHS EED) | Inception through 2006, Issue 3 | www.thecochranelibrary.com
U.S. Centers for Medicare & Medicaid (CMS) Web site | Inception through June 19, 2006 | www.cms.gov Mediregs (www.coverageandpayment.com)
U.S. Food and Drug Administration (FDA) (adverse event reports) | 1977 through June 7, 2006 | www.fda.gov www.ecri.org
U.S. National Guideline Clearinghouse™ (NGC™) | Through June 14, 2006 | www.ngc.gov

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI’s collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature).

## Search Strategies

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across Embase, Medline, and PsycINFO. A parallel strategy was used to search the databases comprising the Cochrane Library.

## Medical Subject Headings (MeSH), Emtree, PsycINFO and Keywords

### Conventions

OVID
$: truncation character (wildcard)
exp: “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy).
.de.: limit controlled vocabulary heading
.fs.: floating subheading
.hw.: limit to heading word
.md.: type of methodology (PsycINFO)
.mp.: combined search fields (default if no fields are specified)
.pt.: publication Type
.ti.: limit to title
.tw.: limit to title and abstract fields

PubMed
[mh]: MeSH heading
[majr]: MeSH heading designated as major topic
[pt]: Publication Type
[sb]: Subset of PubMed database (PreMedline, Systematic, OldMedline)
[sh]: MeSH subheading (qualifiers used in conjunction with MeSH headings)
[tiab]: keyword in title or abstract
[tw]: Text word

CINAHL/Embase/Medline

(English language, human)

Set Number | Concept | Search statement
1 | Cardiac output | exp heart output/ or exp cardiac output/
2 | Hemodynamic monitoring | (hemodynamic monitoring or haemodynamic monitoring or hemodynamic assessment or haemodynamic assessment)
3 | Esophageal doppler | ((esophag$ or oesophag$ or trans?esoph$) and (doppler or ultrasound or son$ or ultrason$ or echocard$)).
4 | Esophageal doppler (controlled vocabulary) | exp transesophageal echocardiography/ or exp echocardiography, transesophageal/
5 | Combine sets | 1 or 2
6 | Combine sets | 3 or 4
7 | Device names | HemoSonic or CardioQ or ODM II or Waki.ti. or Waki.ab. or Dynemo 3000
8 | Combine sets | or/5–7
9 | Limit by publication type | 8 not ((letter or editorial or news or comment or case reports or review or note or conference paper).de. or (letter or editorial or news or comment or case reports or review).pt.)
10 | Limit by study type | 9 and ((Randomized controlled trials or random allocation or double-blind method or single-blind method or placebos or cross-over studies or crossover procedure or double blind procedure or single blind procedure or placebo or latin square design or crossover design or double-blind studies or single-blind studies or triple-blind studies or random assignment or exp controlled study/ or exp clinical trial/ or exp comparative study/ or cohort analysis or follow-up studies.de. or intermethod comparison or parallel design or control group or prospective study or retrospective study or case control study or major clinical study).de. or random$.hw. or random$.ti. or placebo$.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (dummy or blind or sham)).mp. or latin square.mp. or ISRTCN.mp.)

PreMedline (PubMed)

(English language)

Set Number | Concept | Search statement
1 | Doppler cardiac output monitoring | (“cardiac output” OR “hemodynamic assessment” OR “haemodynamic assessment”) AND (doppler OR ultrasound OR ultrason* OR echocard*)
2 | transesophageal | #1 AND (esophag* OR oesophag* OR transesophag* OR transoesophag*)
3 | Combine sets | #1 AND #2
4 | Device names | HemoSonic OR CardioQ OR “ODM II” OR “Waki” [tiab] OR “Dynemo 3000”
5 | Combine sets | #3 OR #4
6 | Limit to Premedline subfile | #5 AND premedline [sb]