# RESULTS

Details of each study are provided in the evidence tables (Appendix D). Below, we provide a summary of the characteristics of these studies and a tabulation of study data. Study results are tabulated in terms of proportion reporting statistically positive results (with regard to either glycemic control or risk factor status) and in terms of effect size (for studies of glycemic control and weight reduction). Note that because health events such as hospitalization were rarely described, these were excluded from the tables summarizing proportion of studies reporting statistically significant intervention effects.

## Characteristics of the Studies Included in the Detailed Review

Design characteristics. Of the 61 included studies, 48 (79 percent) compared a behavioral therapy group to a non-behavioral therapy control group. The remaining 13 studies (21 percent) conducted head-to-head comparisons of different behavioral interventions, treatment intensities, or other aspects of treatment that might modify the effectiveness of behavioral therapies. These latter studies are described in a separate section on effect modifiers.

Types of patients. While all included studies selected patients based on diagnostic criteria for diabetes mellitus (both insulin dependent and non-insulin dependent), there was no evidence that trials sought to systematically include patients whose glycemic control was more or less difficult to manage.

Types of treatment. Of the 48 studies reviewed in detail, the majority (56 percent) evaluated the efficacy of cognitive-behavioral treatment. Of the remainder, six studies (13 percent) examined relaxation-based interventions, 14 studies (29 percent) tested behavioral interventions aimed specifically at diet and/or exercise, and two studies (4 percent) examined blood glucose awareness training.

Intensity of treatment. Thirty-four of the 48 studies (71 percent) reported on the frequency of treatment sessions. Of these 34 studies, the majority (24, 62 percent) reported that treatment sessions were conducted at least weekly, 1 (3 percent) reported treatment sessions were conducted biweekly, 2 (6 percent) reported treatment sessions were conducted monthly, 4 (12 percent) reported treatment sessions were conducted bi-monthly, and 3 (9 percent) reported that that treatment sessions were conducted every three months.

Forty-seven of the 48 articles (98 percent) reported on the duration of the treatment phase of the study. The mean duration of treatment was 33.2 weeks, with the length of treatment varying from 1 to 260 weeks. The mean duration is high due to several studies that had long treatment phases (treatments that lasted 208 weeks to 260 weeks). The duration of treatment for most studies was in the 10 to 20 week range.

Outcomes reported. Per the inclusion criteria, health outcomes were reported in all of the studies. Further, all studies included some measure of metabolic control. Of the 48 articles included, 19 (40 percent) used HbA1c as the primary measure of metabolic control, 7 (15 percent) used HbA1, 16 (33 percent) used GHb, and the remaining 6 studies used fasting blood glucose as the primary metabolic outcome measure.

Thirty of the articles (63 percent) measured weight as an additional health outcome. Of risk factor status measures, 21 (44 percent) reported cholesterol and 9 (19 percent) report blood pressure. Smoking was reported uncommonly (in 2 studies, 4 percent). Other health events were also rarely reported, including health care utilization (reported in 3 studies, 6 percent), and morbidity and mortality (reported in 2 studies, 4 percent).

Quality of life/general health, adjustment, self-efficacy, stress/hassles, distress, and mood measures were also reported in a number of the studies. Of the 48 studies, 6 (12 percent) reported on quality of life and general health, 1 (2 percent) reported on adjustment to diabetes, 1 (2 percent) reported on self-efficacy, 4 (8 percent) reported on stress and hassles, and 2 (4 percent) reported on distress. Regarding mood, 3 (6 percent) reported on anxiety and 3 (6 percent) reported on depression.

Quality of studies. The majority of included studies provided details of the patient characteristics (93 percent), the number of withdrawals and dropouts (83 percent), and described the intervention well enough to allow replication of the study (78 percent). Fewer studies (17, 35 percent) relied on a manual-based treatment protocol or described the methods used to train the individuals administering the intervention (10, 21 percent).

## Overall Efficacy of Treatment

Proportion of positive studies (Table 1). Studies were defined as positive when the behavioral intervention group(s) showed significant improvements on a specific measure in comparison to a non-behavioral control group. Of the 48 randomized trials of behavioral interventions compared to a control, 22 (46 percent) indicated statistically significant improvements in glycemic control. Studies which examined the effect of treatment on risk factors (i.e., weight, cholesterol, blood pressure) were somewhat less often positive, but still positive more often than would be expected by chance alone.

Subjective outcomes were reported for the minority of studies. Proportion of statistically positive studies for subjective measures are as follows: three of six studies measuring quality of life, one of one studies of adjustment, one of one studies of self-efficacy, two of four studies of stress/hassles, zero of two studies of distress, and one of six studies of mood. Thus, overall, subjective measures do not appear to be more likely to be improved than are health outcomes, and, at least for mood, may be somewhat less affected.

Table 1 Overall results: proportion of non-behavioral control studies with statistically positive results (positive studies)

Outcome | Number of Studies | Number of Positive Studies (%)
Glycemic control | 48 | 22 (46)
Risk factor reduction
○ Weight | 30 | 6 (20)
○ Cholesterol | 21 | 8 (38)
○ Blood pressure | 9 | 4 (33)

Proportion of positive studies by study sample size. Treatment outcome was examined as a function of how many patients were randomized to each of the group conditions (Table 2). Studies were grouped into two categories: smaller— those that included fewer than 25 participants per group, and larger—those that include 25 participants per group or more. For glycemic control, larger studies appear to be more commonly positive than smaller studies, whereas the opposite is suggested by the data on risk factor status.

Table 2 Outcome by study size: proportion of studies with statistically positive results (positive studies)

| > 25 per treatment group | | < 25 per treatment group
Outcome | Number of Studies | Number of Positive Studies (%) | Number of Studies | Number of Positive Studies (%)
Glycemic control | 28 | 14 (50) | 20 | 8 (40)
Risk factor status
○ Weight | 20 | 4 (20) | 10 | 2 (20)
○ Cholesterol | 16 | 5 (31) | 5 | 3 (60)
○ Blood pressure | 9 | 3 (33) | – | –

Efficacy of treatment on glycemic control. Of the 48 studies, 29 (60 percent) provided sufficient data to calculate effect size post-treatment (time points less than or equal to 3 months after the end of treatment), corresponding to 37 active interventions evaluated (Figure 1). The mean effect size post-treatment was 0.35 (CI, 0.21 to 0.49) which translates into an absolute decrease in HbA1c of approximately 0.62 percent (CI, 0.32 percent to 0.88 percent). Thirteen of the 48 studies (27 percent) provided sufficient data to calculate effect size at a follow-up point beyond 3 months, corresponding to 19 active interventions evaluated (Figure 2). The mean effect size at follow-up was 0.24 (CI, 0.09 to 0.40), which translates into an absolute decrease in HbA1c of approximately 0.47 percent (CI, 0.18 percent to 0.78 percent). Again, it appears that larger studies tend more often to indicate a positive effect for behavioral therapy on glycemic control.

Efficacy of treatment on weight control. Twenty-six studies (54 percent) included data sufficient to estimate effect size for weight control. As seen in Figure 3, no effect was seen overall or by sample size for this outcome measure.

Figure 1 Impact of treatment on effect size for glycemic control (within 3 months of completing treatment)

* Studies are ordered by decreasing sample size. For key to individual studies, see Appendix C.

Figure 2 Impact of treatment on effect size for glycemic control (at followup beyond 3 months following completion of treatment)

* Studies are ordered by decreasing sample size. For key to individual studies, see Appendix C.

Figure 3 Impact of treatment on effect size for weight control (within 3 months of completing treatment)

* Studies are ordered by decreasing sample size. For key to individual studies, see Appendix C.

Effectiveness vs. time since completion of therapy. To further examine the durability of behavioral therapy in effecting a change in health outcome, we plotted glycemic effect size vs. time since completion of therapy (Figure 4), and weight control effect size vs. time (Figure 5). In both cases there was an unimpressive trend; for glycemic effect there was a negligible trend towards a decay in effectiveness and for weight control a negligible increase in effectiveness over time.

Figure 4 Glycemic Control effect size vs. time since completion of therapy

Figure 5 Weight Control effect size vs. time since completion of therapy

### Efficacy of Treatment by Treatment Characteristics

Efficacy by type of behavioral intervention. Treatment outcome was examined for the four different categories of behavioral intervention: cognitive-behavioral therapy, relaxation-based interventions, diet/exercise interventions, and blood glucose awareness training (Table 3). Proportion of positive studies was similar to the overall results for cognitive-behavioral therapy and behavioral exercise/diet interventions. However, studies of relaxation therapy are less likely to report positive results, and information on blood glucose awareness vs. control intervention are limited.

Table 3 Outcome by treatment type proportion of studies with statistically positive results (positive studies)

| Cognitive- behavioral | | Relaxation | | Diet/exercise | | Blood Glucose Awareness
Outcome | # of Studies | # of Positive Studies (%) | # of Studies | # of Positive Studies (%) | # of Studies | # of Positive Studies (%) | # of Studies | # of Positive Studies (%)
Glycemic control | 26 | 11 (42) | 6 | 2 (33) | 14 | 8 (57) | 2 | 1 (50)
Risk factor reduction
○ Weight | 17 | 3 (18) | 1 | 0 (0) | 12 | 3 (25) | – | –
○ Cholesterol | 12 | 4 (33) | – | – | 9 | 4 (44) | – | –
○ Blood pressure | 4 | 2 (50) | – | – | 5 | 1 (20) | – | –

Figure 6 illustrates the effect sizes ordered by type of treatment. Here we see that both cognitive-behavioral therapy and behavioral diet/exercise programs tend to be more effective than control in improving glycemic control, whereas no clear trend is demonstrated in the more limited studies of relaxation therapy and blood glucose awareness training.

Figure 6 Impact of treatment on effect size for glycemic control within 3 months of completing therapy

* Studies are organized by treatment type (BGAT, Blood Glucose Awareness Therapy; CBT, cognitive-behavioral therapy; D/E, behavioral diet/exercise therapy; relaxation, relaxation therapy). For key to individual studies, see Appendix C.

Efficacy by intensity of treatment. Only one study was identified in which different intensities of therapy were compared head-to-head (Hendricks, 2000). In this study, the investigator compared cognitive-behavioral interventions at monthly and once every 3 month intervals. No significant differences in glycemic control or health care utilization were reported.

For trials in which behavioral therapy was compared to a non-behavioral control, studies were grouped into two intensity categories based on number of sessions: low intensity, those that included less than 14 weekly sessions; and high intensity, those that included 14 or more weekly sessions. The mean number of sessions for the low intensity group was 7.9 and the mean for the high intensity group was 22.8. As seen in Table 4, there was a trend toward a benefit from a greater number of sessions for both glycemic control and risk factor status.

Table 4 Outcomes by treatment intensity: proportion of studies with statistically positive results (positive studies)

| Low Intensity (<14 Sessions) | | High Intensity (≥ 14 Sessions)
Outcome | Number of Studies | Number of Positive Studies (%) | Number of Studies | Number of Positive Studies (%)
Glycemic control | 27 | 13 (48) | 12 | 8 (67)
Risk factor status
○ Weight | 14 | 3 (21) | 8 | 3 (37)
○ Cholesterol | 11 | 6 (54) | 6 | 1 (17)
○ Blood pressure | 1 | 0 (0) | 4 | 2 (50)

In Figures 7 and 8, effect size for glycemic control within 3 months of completing therapy and beyond 3 months of completing therapy is plotted against numbers of interventions. (Note that the results were similar for glycemic control vs. duration of therapy or frequency of therapy (data not shown).) A negligible negative correlation between number of interventions and effect of treatment is noted in the short-term outcomes and a negligible positive correlation is noted in the longer-term outcomes.

Figure 7 Glycemic effect size within 3 months of completing treatment vs. number of interventions

Figure 8 Glycemic effect size beyond 3 months of completing treatment vs. number of interventions

Since type of therapy appeared to influence efficacy, in Figure 9 we examine intensity level within therapy type. There is no evidence that specific therapies are more or less likely to be effective at higher levels of intensity. (Note: a similar plot for effectiveness by intensity and treatment type for glycemic control beyond 3 months of completing therapy also showed no trend (data not shown).)

Figure 9 Impact of treatment on effect size for glycemic control (within 3 months of completing therapy) by intensity (High, more than 14 interventions; Low, 14 or fewer interventions) and treatment type

* For key to individual studies, see Appendix C.

Interaction of glycemic effect and weight effect. Weight control was measured as a risk factor in 30 of the 48 non-behavioral control studies. To examine whether interventions that were more effective in controlling glycemic control were associated with improvements in metabolic control, we plotted the effect size of both, for outcomes within 3 months of completing therapy (Figure 10) and beyond 3 months of completing therapy (Figure 11). A modest positive correlation suggests that the two effects tended to be related.

Figure 10 Weight control effect size as a function of glycemic control effect size within 3 months of completing therapy

Figure 11 Weight control effect size as a function of glycemic control effect size beyond 3 months of completing therapy

Mode of calorie restriction. Five studies conducted head-to-head comparisons of modes of calorie restriction. Wing, Blair, Bononi et al. (1994) showed a significant decrease in fasting glucose means for very low calorie diet (VLCD) when compared to low-calorie diet (LCD) at the end of the 12-week treatment period, but followup data at 15 weeks post-treatment showed no significant differences between the two intervention groups. A similar study, Wing, Blair, Marcus et al. (1994) conducted over a 50-week intervention period showed no significant differences at the end of treatment between VLCD and LCD groups in glycemic or weight control.

Williams (1998) compared standard behavioral therapy to interventions of 1-day and 5-day VLCD over a 20-week period, with no significant differences in HbA1c change means or cholesterol means after treatment.

Both Williams (1999) and Wing (1996) compared varying intensities of VLCDs with weekly meetings over 12- and 20-week periods respectively, neither reporting significant results in metabolic or weight control.

Other potential effect modifiers. Seven studies investigated other modifiers of effect on glycemic control and risk factors, with only one study, Glasgow (2002), reporting significant effect differences between treatment groups.

Large studies of other effect modifiers. Glasgow (2002) compared 4 treatment conditions—basic goal setting, community resources, telephone follow-up and combined condition—on a group of 320 patients over a period of 12 months. Telephone followup showed significant effect when compared to other groups for both glycemic control and lipid ratio (p<0.05).

Glasgow (2003) conducted a large study (N=320) comparing three online interventions—tailored self-management, peer support and information only—over a period of 10 months. No significant differences were reported in glycemic control or lipids ratios between the three groups.

Rickheim (2002) evaluated 170 patients, comparing group vs. individual education, with 4 intervention sessions constituting 5–7 hours of education. There were no significant differences in effect on metabolic or weight control between the groups.

Wing (1985) compared a standard behavioral weight control program to a weight control plus glucose monitoring program, each set of interventions conducted weekly on 25 patients. There were no significant differences between the intervention groups on glycemic or weight control.

Small studies of other effect modifiers. The effect of treatment alone vs. treatment together with a spouse was investigated in Wing (1994) using a 20-week cognitive-behavioral therapy intervention on a total of 49 patients and 49 spouses. No significant differences of effect were reported between the groups for glycemic or weight control.

Lamparski (1989) looked at the effect of current vs. non-current feedback in a blood glucose awareness training (BGAT) program. Interventions were conducted on two 18-patient groups over a period of 4 weeks, with no significant differences in effect between the two groups (current vs. non-current feedback).

Mayer-Davis (2001) conducted a small study (N=33) comparing intensive lifestyle interventions with and without formal evaluation. The 8-week study did not report comparative data between the two groups.