# Key to Figures Illustrating Effect Size

Rec # | Study | Metabolic Control | Intervention | Intervention Category | Size | Intensity | Control | N (total) Subjects | Treatment Length (weeks) | Number of sessions | Sessions/ Week
5220 | Agurs-Collins, 1997 | HbA1c | Group and individual diet and exercise counseling | D/E | Large | High | Usual care | 64 | 24 | 18 | 0.750
460 | Aikens, 1997 | GHb | Theory, guidelines and in-session therapist-guided instruction on relaxation | Relaxation | Small | Low | Usual care | 22 | 8 | 6 | 0.750
2920 | Anderson, 1995 | GHb | Patient empowerment: goal-setting, problem-solving, coping strategies | CBT | Large | Low | Wait list | 64 | 6 | 6 | 1.000
840 | Boehm, 1993 | GHb | Compliance—behaviors related to regimen | CBT | Large | NR | Usual care | 73 | NS | NS | NS
840 | Boehm, 1993 (2) | GHb | Behavioral strategies—analysis sessions with nurse, focused on one strategy | CBT | Large | NR | Usual care | 83 | NS | NS | NS
840 | Boehm, 1993 (3) | GHb | Behavioral strategies with instruction—patient received instruction on strategies | CBT | Large | NR | Usual care | 82 | NS | NS | NS
3830 | Brown, 2002 | HbA1c | Bilingual health behavior—focused on realistic health recommendations | CBT | Large | High | Usual care/ Wait list | 252 | 28 | 26 | 0.929
1440 | Cabrera-Pivaral, 2000 | Glucose means | Behavior modification—changing thoughts, behaviors and feelings through participation techniques | CBT | Small | High | Standard education | 49 | 36 | 36 | 1.000
3400 | Campbell, 1990 | FBG | Intensive group education including visualization | CBT | Large | Low | Conventional education program | 62 | 11 | NS | NS
620 | Campbell, 1996 | HbA1c | Individual sessions plus 3 day small group course focused on diet, exercise, diabetes education | CBT | Large | NR | Minimal intervention | 116 | NS | NS | NS
620 | Campbell, 1996 (2) | HbA1c | Group sessions with information on diet, exercise, diabetes education | CBT | Large | NR | Minimal intervention | 125 | NS | NS | NS
620 | Campbell, 1996 (3) | HbA1c | CBT strategies taught by nurse, focused on eating, exercise and smoking—individual | CBT | Large | NR | Minimal intervention | 115 | NS | NS | NS
6360 | Cox, 1991 | HbA1c | BGAT (standard)—classes with readings and homework and daily recordings of BG cues | BGAT | Small | Low | Control—attended meetings and kept diaries | 27 | 7 | 7 | 1.000
6360 | Cox, 1991 (2) | HbA1c | BGAT (intensive)—immediate feedback during hospitalization | BGAT | Small | Low | Control—attended meetings and kept diaries | 16 | 7 | 7 | 1.000
6250 | D'Eramo-Melkus, 1991 | HbA1c | Group behavioral intervention—lecture sessions on general skills and nutrition, goal-setting | CBT | Large | Low | Minimal skills intervention | 56 | 11 | 11 | 1.000
6250 | D'Eramo-Melkus, 1992 (2) | HbA1c | Group behavioral intervention plus individual followup sessions | CBT | Large | Low | Minimal skills intervention | 54 | 18 | 13 | .7220
20 | Didjurgeit, 2002 | HbA1c | Psycho-therapeutic intervention by one therapist | CBT | Small | High | Wait list | 44 | 14 | 14 | 1.000
510 | Fosbury, 1997 | HbA1 | Cognitive Analytic Therapy (CAT) | CBT | Small | High | Diabetes specialist nurse education | 32 | 16 | 16 | 1.000
330 | Gaede, 1999 | HbA1c | Intensified treatment—standard treatment plus behavior modification and introduction to pharmacological therapy | CBT | Large | High | Standard information | 160 | 208 | 16 | 0.077
210 | Gaede, 2001 | HbA1c | Intensive multifactorial intervention—goal-setting and information on diet, exercise, smoking cessation, self-monitoring | CBT | Large | Low | Standard information | 149 | 24 | NS | NS
6180 | Glasgow, 1992 | GHb | Focused education on dietary and self-care behaviors, problem-solving and coping strategies | CBT | Large | Low | Delayed intervention | 102 | 12 | 10 | 0.833
240 | Glasgow, 2000 | HbA1 | Basic intervention plus telephone follow-up to provide support and reinforcement, personalized problem-solving training | CBT | Large | NR | Basic intervention—interactive multimedia touch-screen assessment | 160 | NS | NS | NS
240 | Glasgow, 2000 (2) | HbA1 | Basic intervention plus community resources—newsletters, goal feedback, food-frequency questionnaire | CBT | Large | NR | Basic intervention—interactive multimedia touch-screen assessment | 160 | NS | NS | NS
240 | Glasgow, 2000 (3) | HbA1 | Combined condition—combination of basic, telephone and community resource follow-up | CBT | Large | NR | Basic intervention—interactive multimedia touch-screen assessment | 160 | NS | NS | NS
3440 | Goldhaber-Fiebert, 2003 | GHb | Lifestyle intervention (in Spanish) focusing on nutrition | D/E | Large | Low | Standard diabetes lecture | 75 | 12 | 11 | 0.917
3220 | Hanefeld, 1991 | FBG | IHE + placebo—patients seen at 3-month intervals | D/E | Large | High | Regular clinical checkups | 760 | 260 | 20 | 0.077
3220 | Hanefeld, 1991 (2) | FBG | IHE + calofibric acid—patients seen at 3-month intervals | D/E | Large | High | Regular clinical checkups | 757 | 260 | 20 | 0.077
4650 | Kinsley, 1999 | HbA1c | BGAT—group training sessions | BGAT | Small | Low | Cholesterol awareness | 47 | 16 | 8 | 0.500
6110 | Laitinen, 1993 | GHb | In-clinic education and goal-setting focusing on nutrition | CBT | Large | Low | Usual care | 86 | 52 | 6 | 0.115
2050 | Lane, 1993 | GHb | Intensive diabetes education plus weekly biofeedback-assisted relaxation training | Relaxation | Small | High | Intensive diabetes education | 38 | 48 | 52 | 1.083
3180 | Maxwell, 1992 | GHb | 5-day training program plus behavioral group therapy—0–3 group meetings | CBT | Large | Low | 5-day small group training program | 180 | 8 | 8 | 1.000
3180 | Maxwell, 1992 (2) | GHb | 5-day training program plus behavioral group therapy—4–8 group meetings | CBT | Large | Low | 5-day small group training program | 117 | 8 | 8 | 1.000
2970 | McGrady, 1991 | Blood glucose means | Biofeedback-assisted relaxation | Relax | Small | Low | Group counseling | 18 | 10 | 10 | 1.000
350 | McGrady, 1999 | GHb | 45-minute sessions of biofeedback assisted relaxation | Relaxation | Small | High | Usual care/ glucose monitoring | 18 | 8 to 15 | 12 | NS
2370 | Oh, 2003 | HbA1c | Telephone intervention—continuous education reinforcement | D/E | Small | High | Usual care | 38 | 12 | 16 | 1.333
2910 | Perry, 1997 | HbA1c | Monthly meetings, individualized diet and exercise prescriptions, fitness appraisal | D/E | Large | Low | Standard care once every 3 months | 61 | NS | NS | NS
3200 | Rost, 1991 | GHb | Patient activation intervention—focusing on decision making and information seeking | CBT | Large | Low | Standard evaluation and education | 61 | 0.14 | 2 | 14.286
550 | Smith, 1997 | GHb | Behavioral weight control (group) plus three individualized motivational interviews | CBT | Small | High | Behavioral weight control (group) | 16 | 16 | 16 | 1.000
2360 | Trento, 2002 | HbA1c | Group education sessions focusing on multiple factors | CBT | Large | High | Individual diabetes education | 112 | 208 | 16 | 0.077
6240 | Vanninen, 1992 (men) | HbA1c | Physician distributed information on exercise | D/E | Small | Low | Basic information sessions | 45 | 52 | 6 | 0.115
6240 | Vanninen, 1992 (women) | HbA1c | Physician distributed information on exercise | D/E | Small | Low | Basic information sessions | 32 | 52 | 6 | 0.115