# Search Strategies

## Search Strategy 1: Behavioral Therapy for Diabetes Mellitus

1. exp "behavioral disciplines and activities"/ or cognitive therapy/
2. exp Diabetes Mellitus/
3. 1 and 2
4. randomized controlled trials/
5. random allocation/
6. double-blind method/
7. single-blind method/
8. randomized controlled trial.pt.
9. 4 or 5 or 6 or 7 or 8
10. animal/
11. human/
12. 10 and 11
13. 10 not 12
14. 9 not 13
15. clinical trial.pt.
16. exp clinical trials/
17. (clin$ adj trial$).tw.
18. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw.
19. placebos/
20. placebo$.tw.
21. random$.tw.
22. research design/
23. 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22
24. 23 not 13
25. comparative-study/
26. exp evaluation studies/
27. follow-up studies/
28. prospective-studies/
29. (control$ or prospectiv$ or volunteer$).tw.
30. 25 or 26 or 27 or 28 or 29
31. 30 not 13
32. 24 not 14
33. 31 not (24 or 14)
34. 3 and 14
35. 3 and 32
36. 3 and 33
37. limit 3 to (human and english language)
38. 37 and 14
39. 37 and 32
40. 37 and 33

## Search Strategy 2: Patient Education and Diabetes Mellitus

Database: MEDLINE <1966 to June Week 3 2003>

1 | randomized controlled trial.pt. (176910)
2 | controlled clinical trial.pt. (63666)
3 | Randomized Controlled Trials/ (29246)
4 | Random Allocation/ (48831)
5 | Double-Blind Method/ (74469)
6 | Single-Blind Method/ (7355)
7 | or/1–6 (300346)
8 | Animal/ not Human/ (2682706)
9 | 7 not 8 (285640)
10 | clinical trial.pt. (360658)
11 | exp Clinical Trials/ (147492)
12 | (clinic$ adj25 trial$).tw. (91610)
13 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (71153)
14 | Placebos/ (23020)
15 | placebo$.tw. (79266)
16 | random$.tw. (263309)
17 | Research Design/ (37382)
18 | (latin adj square).tw. (1990)
19 | or/10–18 (629578)
20 | 19 not 8 (584818)
21 | 20 not 9 (308889)
22 | Comparative Study/ (1052532)
23 | exp Evaluation Studies/ (462029)
24 | Follow-Up Studies/ (269186)
25 | Prospective Studies/ (162165)
26 | (control$ or prospectiv$ or volunteer$).tw. (1344071)
27 | Cross-Over Studies/ (12786)
28 | or/22–27 (2712604)
29 | 28 not 8 (2074987)
30 | 29 not (9 or 21) (1663527)
31 | 9 or 21 or 30 (2258056)
32 | Patient Education/ (36623)
33 | 31 and 32 (8854)
34 | exp Diabetes Mellitus/ (161644)
35 | 33 and 34 (1243)
36 | limit 35 to english language (1046)
37 | 36 and (9 or 21) (366)
38 | from 37 keep 1–366 (366)