# Description of Health and Behavior Assessment/Intervention CPT codes

(Excerpted from American Medical Association’s Current Procedural Terminology, CPT 2004, Chicago, IL: AMA)

Code | Description
96150 | Health and behavior assessment (e.g., health-focused clinical interview, behavioral observations, psychophysiological monitoring, health-oriented questionnaires), each 15 minutes face-to-face with the patient; initial assessment
96151 | Re-assessment
96152 | Health and behavior intervention, each 15 minutes, face-to-face; individual
96153 | Group (2 or more patients)
96154 | Family (with the patient present)
96155 | Family (without the patient present)