# BIBLIOGRAPHY

### Included Studies

1 Agurs-Collins TD, Kumanyika SK, Ten Have TR, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20(10):1503-1511. [pmid: 9314625].
2 Aikens JE, Kiolbasa TA, Sobel R. Psychological predictors of glycemic change with relaxation training in non-insulin-dependent diabetes mellitus. Psychother Psychosom. 1997;66(6):302-306. [pmid: 9403919].
3 Anderson RM, Funnell MM, Butler PM, et al. Patient empowerment. Results of a randomized controlled trial. Diabetes Care. 1995;18(7):943-949. [pmid: 7555554].
4 Boehm S, Schlenk EA, Raleigh E, et al. Behavioral analysis and behavioral strategies to improve self-management of type II diabetes. Clin Nursing Res. 1993;2(3):327-344.
5 Brown SA, Garcia AA, Kouzekanani K, et al. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. 2002;25(2):259-268. [pmid: 11815493].
6 Cabrera-Pivaral CE, Gonzalez-Perez G, Vega-Lopez G, et al. Effects of behaviour-modifying education in the metabolic profile of the type 2 diabetes mellitus patient. J Diabetes Complications. 2000;14(6):322-326. [pmid: 11120456].
7 Campbell EM, Redman S, Moffitt PS, et al. The relative effectiveness of educational and behavioral instruction programs for patients with NIDDM: a randomized trial. Diabetes Educ. 1996;22(4):379-386. [pmid: 8846745].
8 Campbell LV, Barth R, Gosper JK, et al. Impact of intensive educational approach to dietary change in NIDDM. Diabetes Care. 1990;13(8):841-847. [pmid: 2209318].
9 Cox DJ, Gonder-Frederick L, Julian D, et al. Intensive versus standard blood glucose awareness training (BGAT) with insulin-dependent diabetes: mechanisms and ancillary effects. Psychosom Med. 1991;53(4):453-462. [pmid: 1924656].
10 D'Eramo-Melkus GA, Wylie-Rosett J, Hagan JA. Metabolic impact of education in NIDDM. Diabetes Care. 1992;15(7):864-869. [pmid: 1516506].
11 Didjurgeit U, Kruse J, Schmitz N, et al. A time-limited, problem-orientated psychotherapeutic intervention in Type 1 diabetic patients with complications: a randomized controlled trial. Diabetic Med. 2002;19(10):814-821. [pmid: 12358867].
12 Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metab Clin Exper. Suppl 1. 1997;46(12):50-55. [pmid: 9439560].
13 Fosbury JA, Bosley CM, Ryle A, et al. A trial of cognitive analytic therapy in poorly controlled type I patients. Diabetes Care. 1997;20(6):959-964. [pmid: 9167106].
14 Gaede P, Beck M, Vedel P, et al. Limited impact of lifestyle education in patients with Type 2 diabetes mellitus and microalbuminuria: results from a randomized intervention study. Diabetic Med. 2001;18(2):104-108. [pmid: 11251672].
15 Gaede P, Vedel P, Parving HH, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-622. [pmid: 10030326].
16 Glasgow RE, Boles SM, McKay HG, et al. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med. 2003;36(4):410-419. [pmid: 12649049].
17 Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Pat Educ Counsel. 1997;32(3):175-184.
18 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-1073. [pmid: 11078048].
19 Glasgow RE, Toobert DJ, Hampson SE. Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care. 1996;19(8):835-842. [pmid: 8842601].
20 Glasgow RE, Toobert DJ, Hampson SE, et al. Improving self-care among older patients with type II diabetes: the "Sixty Something.." Study. Pat Educ Counsel. 1992;19(1):61-74.
21 Glasgow RE, Toobert DJ, Hampson SE, et al. Implementation, generalization and longterm results of the "choosing well" diabetes self-management intervention. Pat Educ Counsel. 2002;48(2):115-122.
22 Glasgow RE, Toobert DJ, Mitchell DL, et al. Nutrition education and social learning interventions for type II diabetes. Diabetes Care. 1989;12(2):150-152. [pmid: 2702897].
23 Goldhaber-Fiebert JD, Goldhaber-Fiebert SN, Tristan ML, et al. Randomized controlled community-based nutrition and exercise intervention improves glycemia and cardiovascular risk factors in type 2 diabetic patients in rural Costa Rica. Diabetes Care. 2003;26(1):24-29. [pmid: 12502654].
24 Greenfield S, Kaplan SH, Ware JE Jr, et al. Patients' participation in medical care: effects on blood sugar control and quality of life in diabetes. J Gen Int Med. 1988;3(5):448-457.
25 Hanefeld M, Fischer S, Schmechel H, et al. Diabetes Intervention Study. Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. 1991;14(4):308-317. [pmid: 2060433].
26 Hartwell SL, Kaplan RM, Wallace JP. Comparison of behavioral interventions for control of type II-diabetes-mellitus. Behav Ther. 1986;17(4):447-461.
27 Heitzmann CA, Kaplan RM, Wilson DK, et al. Sex differences in weight loss among adults with type II diabetes mellitus. J Behav Med. 1987;10(2):197-211. [pmid: 3612778].
28 Hendricks LE, Hendricks RT. The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ. 2000;26(6):995-1002. [pmid: 11912812].
29 Kaplan RM, Hartwell SL, Wilson DK, et al. Effects of diet and exercise interventions on control and quality of life in non-insulin-dependent diabetes mellitus. J Gen Int Med. 1987;2(4):220-228.
30 Kinsley BT, Weinger K, Bajaj M, et al. Blood glucose awareness training and epinephrine responses to hypoglycemia during intensive treatment in type 1 diabetes. Diabetes Care. 1999;22(7):1022-1028. [pmid: 10388961].
31 Laitinen JH, Ahola IE, Sarkkinen ES, et al. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1993;93(3):276-283. [pmid: 8382712].
32 Lamparski DM, Wing RR. Blood glucose discrimination training in patients with type II diabetes. Biofeedback Self Regulation. 1989;14(3):195-206. [pmid: 2597711].
33 Lane JD, McCaskill CC, Ross SL, et al. Relaxation training for NIDDM. Predicting who may benefit. Diabetes Care. 1993;16(8):1087-1094. [pmid: 8375238].
34 Lustman PJ, Griffith LS, Freedland KE, et al. Cognitive behavior therapy for depression in type 2 diabetes mellitus. A randomized, controlled trial. Ann Int Med. 1998;129(8):613-621. [pmid: 9786808].
35 Manning RM, Jung RT, Leese GP, et al. The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabetic Med. 1995;12(5):409-415. [pmid: 7648803].
36 Manning RM, Jung RT, Leese GP, et al. The comparison of four weight reduction strategies aimed at overweight patients with diabetes mellitus: four-year follow-up. Diabetic Med. 1998;15(6):497-502. [pmid: 9632125].
37 Maxwell AE, Hunt IF, Bush MA. Effects of a social support group, as an adjunct to diabetes training, on metabolic control and psychosocial outcomes. Diabetes Educ. 1992;18(4):303-309. [pmid: 1628531].
38 Mayer-Davis EJ, D'Antonio A, Martin M, et al. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds Off with Empowerment (POWER). Fam Comm Health. 2001;24(2):27-35.
39 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. 1986;9(1):1-10. [pmid: 3948638].
40 McGrady A, Bailey BK, Good MP. Controlled study of biofeedback-assisted relaxation in type I diabetes. Diabetes Care. 1991;14(5):360-365. [pmid: 2060447].
41 McGrady A, Horner J. Role of mood in outcome of biofeedback assisted relaxation therapy in insulin dependent diabetes mellitus. Appl Psychophysiol Biofeedback. 1999;24(1):79-88. [pmid: 10553485].
42 Oh JA, Kim HS, Yoon KH, et al. A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J. 2003;44(1):1-8. [pmid: 12619168].
43 Perry TL, Mann JI, Lewis-Barned NJ, et al. Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). Eur J Clin Nutr. 1997;51(11):757-763. [pmid: 9368810].
44 Rabkin SW, Boyko E, Wilson A, et al. A randomized clinical trial comparing behavior modification and individual counseling in the nutritional therapy of non-insulin-dependent diabetes mellitus: comparison of the effect on blood sugar, body weight, and serum lipids. Diabetes Care. 1983;6(1):50-56. [pmid: 6341015].
45 Rickheim PL, Weaver TW, Flader JL, et al. Assessment of group versus individual diabetes education: a randomized study. Diabetes Care. 2002;25(2):269-274. [pmid: 11815494].
46 Ridgeway NA, Harvill DR, Harvill LM, et al. Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. Southern Med J. 1999;92(7):667-672. [pmid: 10414474].
47 Rost KM, Flavin KS, Cole K, et al. Change in metabolic control and functional status after hospitalization. Impact of patient activation intervention in diabetic patients. Diabetes Care. 1991;14(10):881-889. [pmid: 1773686].
48 Sadur CN, Moline N, Costa M, et al. Diabetes management in a health maintenance organization. Efficacy of care management using cluster visits. Diabetes Care. 1999;22(12):2011-2017. [pmid: 10587835].
49 Smith DE, Heckemeyer CM, Kratt PP, et al. Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care. 1997;20(1):52-54. [pmid: 9028693].
50 Surwit RS, van Tilburg MA, Zucker N, et al. Stress management improves long-term glycemic control in type 2 diabetes. Diabetes Care. 2002;25(1):30-34. [pmid: 11772897].
51 Trento M, Passera P, Bajardi M, et al. Lifestyle intervention by group care prevents deterioration of Type II diabetes: a 4-year randomized controlled clinical trial. Diabetologia. 2002;45(9):1231-1239. [pmid: 12242455].
52 Vanninen E, Uusitupa M, Siitonen O, et al. Habitual physical activity, aerobic capacity and metabolic control in patients with newly-diagnosed type 2 (non-insulin-dependent) diabetes mellitus: effect of 1-year diet and exercise intervention. Diabetologia. 1992;35(4):340-346. [pmid: 1516762].
53 White N, Carnahan J, Nugent CA, et al. Management of obese patients with diabetes mellitus: comparison of advice education with group management. Diabetes Care. 1986;9(5):490-496. [pmid: 3769719].
54 Williams KV, Mullen M, Lang W, et al. Weight loss and leptin changes in individuals with type 2 diabetes. Obesity Res. 1999;7(2):155-163.
55 Williams KV, Mullen ML, Kelley DE, et al. The effect of short periods of caloric restriction on weight loss and glycemic control in type 2 diabetes. Diabetes Care. 1998;21(1):2-8. [pmid: 9538962].
56 Wing RR, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19(5):409-413. [pmid: 8732700].
57 Wing RR, Blair E, Marcus M, et al. Year-long weight loss treatment for obese patients with type II diabetes: does including an intermittent very-low-calorie diet improve outcome?. Am J Med. 1994;97(4):354-362. [pmid: 7942937].
58 Wing RR, Blair EH, Bononi P, et al. Caloric restriction per se is a significant factor in improvements in glycemic control and insulin sensitivity during weight loss in obese NIDDM patients. Diabetes Care. 1994;17(1):30-36. [pmid: 8112186].
59 Wing RR, Epstein LH, Nowalk MP, et al. Behavior change, weight loss, and physiological improvements in type II diabetic patients. J Consult Clin Psychol. 1985;53(1):111-122. [pmid: 3980816].
60 Wing RR, Epstein LH, Nowalk MP, et al. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. Am J Med. 1986;81(5):830-836. [pmid: 3535493].
61 Wing RR, Marcus MD, Epstein LH, et al. A "family-based" approach to the treatment of obese type II diabetic patients. J Consult Clin Psychol. 1991;59(1):156-162. [pmid: 2002132].

### Excluded Studies

1 Abraira C, Emanuele N, Colwell J, et al. Glycemic control and complications in type II diabetes. Design of a feasibility trial. VA CS Group (CSDM). Diabetes Care. 1992;15(11):1560-1571. [pmid: 1308130].
2 Agurs-Collins TD, Kumanyika SK, Ten Have TR, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20(10):1503-1511. [pmid: 9314625].
3 Ahring KK, Ahring JP, Joyce C, et al. Telephone modem access improves diabetes control in those with insulin-requiring diabetes. Diabetes Care. 1992;15(8):971-975. [pmid: 1505329].
4 Aikens JE, Kiolbasa TA, Sobel R. Psychological predictors of glycemic change with relaxation training in non-insulin-dependent diabetes mellitus. Psychother Psychosom. 1997;66(6):302-306. [pmid: 9403919].
5 Anderson BJ, Wolf FM, Burkhart MT, et al. Effects of peer-group intervention on metabolic control of adolescents with IDDM. Randomized outpatient study. Diabetes Care. 1989;12(3):179-183. [pmid: 2649330].
6 Anderson RJ, Grigsby AB, Freedland KE, et al. Anxiety and poor glycemic control: a meta-analytic review of the literature. [Review]. Internat J Psych Med. 2002;32(3):235-247.
7 Anderson RM, Funnell MM, Butler PM, et al. Patient empowerment. Results of a randomized controlled trial. Diabetes Care. 1995;18(7):943-949. [pmid: 7555554].
8 Anonymous. The absence of a glycemic threshold for the development of long-term complications: the perspective of the Diabetes Control and Complications Trial. Diabetes. 1996;45(10):1289-1298. [pmid: 8826962].
9 Anonymous. The Diabetes Prevention Program: baseline characteristics of the randomized cohort. The Diabetes Prevention Program Research Group. Diabetes Care. 2000;23(11):1619-1629. [pmid: 11092283].
10 Arseneau DL, Mason AC, Wood OB, et al. A comparison of learning activity packages and classroom instruction for diet management of patients with non-insulin-dependent diabetes mellitus. Diabetes Educ. 1994;20(6):509-514. [pmid: 7851264].
11 Barrera M Jr, Glasgow RE, McKay HG, et al. Do Internet-based support interventions change perceptions of social support?: An experimental trial of approaches for supporting diabetes self-management. Am J Comm Psychol. 2002;30(5):637-654.
12 Benjamin EM, Schneider MS, Hinchey KT. Implementing practice guidelines for diabetes care using problem-based learning. A prospective controlled trial using firm systems. Diabetes Care. 1999;22(10):1672-1678. [pmid: 10526733].
13 Bloomgarden ZT, Karmally W, Metzger MJ, et al. Randomized, controlled trial of diabetic patient education: improved knowledge without improved metabolic status. Diabetes Care. 1987;10(3):263-272. [pmid: 3297575].
14 Boehm S, Schlenk EA, Raleigh E, et al. Behavioral analysis and behavioral strategies to improve self-management of type II diabetes. Clin Nursing Res. 1993;2(3):327-344.
15 Boraz MA, Simkin-Silverman LR, Wing RR, et al. Hormone replacement therapy use and menopausal symptoms among women participating in a behavioral lifestyle intervention. Prev Med. 2001;33(2 Pt 1):108-114. [pmid: 11493043].
16 Brown SA. Meta-analysis of diabetes patient education research: variations in intervention effects across studies. Res Nurs Health. 1992;15(6):409-419. [pmid: 1448572].
17 Brown SA. Interventions to promote diabetes self-management: state of the science. [Review]. Diabetes Educ. 1999;25(6 Suppl):52-61. [pmid: 10711085].
18 Brown SA, Garcia AA, Kouzekanani K, et al. Culturally competent diabetes selfmanagement education for Mexican Americans: the Starr County border health initiative. Diabetes Care. 2002;25(2):259-268. [pmid: 11815493].
19 Brown SA, Hanis CL. Culturally competent diabetes education for Mexican Americans: the Starr County Study. Diabetes Educ. 1999;25(2):226-236. [pmid: 10531848].
20 Burroughs TE, Harris MA, Pontious SL, et al. Research on social support in adolescents with IDDM: a critical review. [Review]. Diabetes Educ. 1997;23(4):438-448. [pmid: 9305010].
21 Cabrera-Pivaral CE, Gonzalez-Perez G, Vega-Lopez G, et al. Effects of behaviour-modifying education in the metabolic profile of the type 2 diabetes mellitus patient. J Diabetes Complications. 2000;14(6):322-326. [pmid: 11120456].
22 Cagliero E, Levina EV, Nathan DM. Immediate feedback of HbA1c levels improves glycemic control in type 1 and insulin-treated type 2 diabetic patients. Diabetes Care. 1999;22(11):1785-1789. [pmid: 10546008].
23 Calle-Pascual AL, Rodriguez C, Camacho F, et al. Behaviour modification in obese subjects with type 2 diabetes mellitus. Diabetes Res Clin Pract. 1992;15(2):157-162. [pmid: 1563332].
24 Campbell EM, Redman S, Moffitt PS, et al. The relative effectiveness of educational and behavioral instruction programs for patients with NIDDM: a randomized trial. Diabetes Educ. 1996;22(4):379-386. [pmid: 8846745].
25 Campbell LV, Barth R, Gosper JK, et al. Impact of intensive educational approach to dietary change in NIDDM. Diabetes Care. 1990;13(8):841-847. [pmid: 2209318].
26 Clark M, Hampson SE. Implementing a psychological intervention to improve lifestyle self-management in patients with type 2 diabetes. Pat Educ Counsel. 2001;42(3):247-256.
27 Clark M, Hampson SE. Implementing a psychological intervention to improve lifestyle self-management in patients with type 2 diabetes. Pat Educ Counsel. 2001;42(3):247-256.
28 Colagiuri S, Colagiuri R, Naidu V. Diabetes simulation: an effective method for teaching diabetes to medical students. Diabetes Educ. 153. 1994;20(2):151-154. [pmid: 7851229].
29 Collins FM. Current treatment approaches to type 2 diabetes mellitus: successes and shortcomings. [Review]. Am J Manag Care. 2002;8(16 Suppl):S460-S471. [pmid: 12408409].
30 Corbett CF. Research-based practice implications for patients with diabetes. Part II: Diabetes self-efficacy. Home Healthcare Nurse. 1999;17(9):587-596. [pmid: 10763657].
31 Corbett CF. A randomized pilot study of improving foot care in home health patients with diabetes. Diabetes Educ. 2003;29(2):273-282. [pmid: 12728754].
32 Cox D, Gonder-Frederick L, Polonsky W, et al. A multicenter evaluation of blood glucose awareness training-II. Diabetes Care. 1995;18(4):523-528. [pmid: 7497863].
33 Cox DJ, Gonder-Frederick L. Major developments in behavioral diabetes research. [Review]. J Consult Clin Psychol. 1992;60(4):628-638. [pmid: 1506511].
34 Cox DJ, Gonder-Frederick L, Julian D, et al. Intensive versus standard blood glucose awareness training (BGAT) with insulin-dependent diabetes: mechanisms and ancillary effects. Psychosom Med. 1991;53(4):453-462. [pmid: 1924656].
35 Cox DJ, Gonder-Frederick L, Julian DM, et al. Long-term follow-up evaluation of blood glucose awareness training. Diabetes Care. 1994;17(1):1-5. [pmid: 8112183].
36 Cox DJ, Gonder-Frederick L, Polonsky W, et al. Blood glucose awareness training (BGAT(2): long-term benefits. Diabetes Care. 2001;24(4):637-642. [pmid: 11315822].
37 D'Eramo-Melkus GA, Wylie-Rosett J, Hagan JA. Metabolic impact of education in NIDDM. Diabetes Care. 1992;15(7):864-869. [pmid: 1516506].
38 DAFNE Study Group. Training in flexible, intensive insulin management to enable dietary freedom in people with type 1 diabetes: dose adjustment for normal eating (DAFNE) randomised controlled trial. BMJ. 2002;325(7367):746. [pmid: 12364302].
39 Dagogo-Jack S. DCCT results and diabetes care in developing countries. Diabetes Care. 1995;18(3):416-417. [pmid: 7555491].
40 de Weerdt I, Visser AP, Kok GJ, et al. Randomized controlled multicentre evaluation of an education programme for insulin-treated diabetic patients: effects on metabolic control, quality of life, and costs of therapy. Diabetic Med. 1991;8(4):338-345. [pmid: 1830257].
41 Deckers S, Hermans MP, Buysschaert M. Therapy, glycaemic control and complications in type 1 diabetic patients: results from a single centre cohort of 465 subjects. Acta Clin Belgica. 2001;56(5):289-296.
42 Delamater AM, Bubb J, Davis SG, et al. Randomized prospective study of self-management training with newly diagnosed diabetic children.[erratum appears in Diabetes Care 1990 Jul;13(7)819]. Diabetes Care. 1990;13(5):492-498. [pmid: 2351027].
43 Delamater AM, Jacobson AM, Anderson B, et al. Psychosocial therapies in diabetes: report of the Psychosocial Therapies Working Group. [Review]. Diabetes Care. 2001;24(7):1286-1292. [pmid: 11423517].
44 Didjurgeit U, Kruse J, Schmitz N, et al. A time-limited, problem-orientated psychotherapeutic intervention in Type 1 diabetic patients with complications: a randomized controlled trial. Diabetic Med. 2002;19(10):814-821. [pmid: 12358867].
45 Dunn SM, Beeney LJ, Hoskins PL, et al. Knowledge and attitude change as predictors of metabolic improvement in diabetes education. Soc Sci Med. 1990;31(10):1135-1141. [pmid: 2274802].
46 Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metab Clin Exper. Suppl 1. 1997;46(12):50-55. [pmid: 9439560].
47 Eakin EG, Bull SS, Glasgow RE, et al. Reaching those most in need: a review of diabetes self-management interventions in disadvantaged populations. [Review]. Diabetes/Metab Res Revs. 2002;18(1):26-35.
48 Estey AL, Tan MH, Mann K. Follow-up intervention: its effect on compliance behavior to a diabetes regimen. Diabetes Educ. 1990;16(4):291-295. [pmid: 2357919].
49 Fain JA, Nettles A, Funnell MM, et al. Diabetes patient education research: an integrative literature review. [Review]. Diabetes Educ. 1999;25(6 Suppl):7-15. [pmid: 10711080].
50 Falkenberg MG, Elwing BE, Goransson AM, et al. Problem oriented participatory education in the guidance of adults with non-insulin-treated type-II diabetes mellitus. Scand J Primary Health Care. 1986;4(3):157-164.
51 Feinglos MN, Hastedt P, Surwit RS. Effects of relaxation therapy on patients with type I diabetes mellitus. Diabetes Care. 1987;10(1):72-75. [pmid: 3552516].
52 Field AE, Wing RR, Manson JE, et al. Relationship of a large weight loss to long-term weight change among young and middle-aged US women. Internat J Obesity Related Metabol Dis. 2001;25(8):1113-1121.
53 Fosbury JA, Bosley CM, Ryle A, et al. A trial of cognitive analytic therapy in poorly controlled type I patients. Diabetes Care. 1997;20(6):959-964. [pmid: 9167106].
54 Franz MJ, Monk A, Barry B, et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. J Am Diet Assoc. 1995;95(9):1009-1017. [pmid: 7657902].
55 Friedman RH. Automated telephone conversations to assess health behavior and deliver behavioral interventions. J Med Systems. 1998;22(2):95-102.
56 Frost G, Lyons F, Bovill-Taylor C, et al. Intensive lifestyle intervention combined with the choice of pharmacotherapy improves weight loss and cardiac risk factors in the obese. J Human Nutr Diet. 2002;15(4):287-295. quiz 297–9. [pmid: 12153502].
57 Gaede P, Beck M, Vedel P, et al. Limited impact of lifestyle education in patients with Type 2 diabetes mellitus and microalbuminuria: results from a randomized intervention study. Diabetic Med. 2001;18(2):104-108. [pmid: 11251672].
58 Gaede P, Vedel P, Parving HH, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-622. [pmid: 10030326].
59 Galper DI, Tayulor AG, Cox DJ. Current status of mind-body interventions for vascular complications of diabetes. Fam Comm Health. 2003;26(1):34-40.
60 Garcia AA, Villagomez ET, Brown SA, et al. The Starr County Diabetes Education Study: development of the Spanish-language diabetes knowledge questionnaire.[erratum appears in Diabetes Care 2001 May;24(5)972]. Diabetes Care. 2001;24(1):16-21. [pmid: 11194219].
61 Gary TL, Batts ML, Bone L, et al. Effect of behavioral interventions on body-mass index, diet, and physical activity in urban African Americans with type 2 diabetes. Diabetes. 1999;48:0157.
62 Gilden JL, Hendryx MS, Clar S, et al. Diabetes support groups improve health care of older diabetic patients. J Am Geriatrics Society. 1992;40(2):147-150.
63 Gilliland SS, Azen SP, Perez GE, et al. Strong in body and spirit: lifestyle intervention for Native American adults with diabetes in New Mexico. Diabetes Care. 2002;25(1):78-83. [pmid: 11772905].
64 Glasgow RE. Diabetes education research. Diabetes Educ. 1999;25(6 Suppl):5-6. [pmid: 10711079].
65 Glasgow RE, Anderson BJ. Future directions for research on pediatric chronic disease management: lessons from diabetes. [Review]. J Ped Psychol. 1995;20(4):389-402.
66 Glasgow RE, Boles SM, McKay HG, et al. The D-Net diabetes self-management program: long-term implementation, outcomes, and generalization results. Prev Med. 2003;36(4):410-419. [pmid: 12649049].
67 Glasgow RE, Bull SS, Gillette C, et al. Behavior change intervention research in healthcare settings: a review of recent reports with emphasis on external validity. [Review]. Am J Prev Med. 2002;23(1):62-69. [pmid: 12093425].
68 Glasgow RE, Fisher EB, Anderson BJ, et al. Behavioral science in diabetes. Contributions and opportunities. [Review]. Diabetes Care. 1999;22(5):832-843. [pmid: 10332691].
69 Glasgow RE, La Chance PA, Toobert DJ, et al. Long-term effects and costs of brief behavioural dietary intervention for patients with diabetes delivered from the medical office. Pat Educ Counsel. 1997;32(3):175-184.
70 Glasgow RE, Osteen VL. Evaluating diabetes education. Are we measuring the most important outcomes? [Review]. Diabetes Care. 1992;15(10):1423-1432. [pmid: 1425111].
71 Glasgow RE, Toobert DJ. Brief, computer-assisted diabetes dietary self-management counseling: effects on behavior, physiologic outcomes, and quality of life. Med Care. 2000;38(11):1062-1073. [pmid: 11078048].
72 Glasgow RE, Toobert DJ, Hampson SE. Effects of a brief office-based intervention to facilitate diabetes dietary self-management. Diabetes Care. 1996;19(8):835-842. [pmid: 8842601].
73 Glasgow RE, Toobert DJ, Hampson SE, et al. Improving self-care among older patients with type II diabetes: the "Sixty Something.." Study. Pat Educ Counsel. 1992;19(1):61-74.
74 Glasgow RE, Toobert DJ, Hampson SE, et al. A brief office-based intervention to facilitate diabetes dietary self-management. Health Educ Res. 1995;10(4):467-478. [pmid: 10159676].
75 Glasgow RE, Toobert DJ, Hampson SE, et al. Implementation, generalization and long-term results of the "choosing well" diabetes self-management intervention. Pat Educ Counsel. 2002;48(2):115-122.
76 Glasgow RE, Toobert DJ, Mitchell DL, et al. Nutrition education and social learning interventions for type II diabetes. Diabetes Care. 1989;12(2):150-152. [pmid: 2702897].
77 Goldhaber-Fiebert JD, Goldhaber-Fiebert SN, Tristan ML, et al. Randomized controlled community-based nutrition and exercise intervention improves glycemia and cardiovascular risk factors in type 2 diabetic patients in rural Costa Rica. Diabetes Care. 2003;26(1):24-29. [pmid: 12502654].
78 Goodall TA, Halford WK. Self-management of diabetes mellitus: a critical review.[erratum appears in Health Psychol 1992; 11(1)77]. [Review]. Health Psychol. 1991;10(1):1-8. [pmid: 2026125].
79 Graber AL, Elasy TA, Quinn D, et al. Improving glycemic control in adults with diabetes mellitus: shared responsibility in primary care practices. Southern Med J. 2002;95(7):684-690. [pmid: 12144072].
80 Greenfield S, Kaplan SH, Ware JE Jr, et al. Patients' participation in medical care: effects on blood sugar control and quality of life in diabetes. J Gen Int Med. 1988;3(5):448-457.
81 Hanefeld M, Fischer S, Schmechel H, et al. Diabetes Intervention Study. Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. 1991;14(4):308-317. [pmid: 2060433].
82 Hartwell SL, Kaplan RM, Wallace JP. Comparison of behavioral interventions for control of type II-diabetes-mellitus. Behav Ther. 1986;17(4):447-461.
83 Heitzmann CA, Kaplan RM. Interaction between sex and social support in the control of type II diabetes mellitus. J Consult Clin Psychol. 1984;52(6):1087-1089. [pmid: 6520278].
84 Heitzmann CA, Kaplan RM, Wilson DK, et al. Sex differences in weight loss among adults with type II diabetes mellitus. J Behav Med. 1987;10(2):197-211. [pmid: 3612778].
85 Heller SR, Clarke P, Daly H, et al. Group education for obese patients with type 2 diabetes: greater success at less cost. Diabetic Med. 1988;5(6):552-556. [pmid: 2974778].
86 Hendricks LE, Hendricks RT. The effect of diabetes self-management education with frequent follow-up on the health outcomes of African American men. Diabetes Educ. 2000;26(6):995-1002. [pmid: 11912812].
87 Hentzen DH. From the president: the results of the Diabetes Control and Complications Trial. Diabetes Educ. 1994;20(2):103. [pmid: 7851221].
88 Hiss RG, Gillard ML, Armbruster BA, et al. Comprehensive evaluation of community-based diabetic patients: effect of feedback to patients and their physicians: a randomized controlled trial. Diabetes Care. 2001;24(4):690-694. [pmid: 11315832].
89 Home P, Chacra A, Chan J, et al. Considerations on blood glucose management in Type 2 diabetes mellitus. [Review]. Diabetes/Metab Res Revs. 2002;18(4):273-285.
90 Horwitz BL. Cooperative learning as an approach for educating diabetic patients and their spouses. J NY State Nurs Assoc. 1993;24(3):15-17.
91 Howorka K, Pumprla J, Wagner-Nosiska D, et al. Empowering diabetes out-patients with structured education: short-term and long-term effects of functional insulin treatment on perceived control over diabetes. J Psychosom Res. 2000;48(1):37-44. [pmid: 10750628].
92 Jablon SL, Naliboff BD, Gilmore SL, et al. Effects of relaxation training on glucose tolerance and diabetic control in type II diabetes. Appl Psychophysiol Biofeedback. 1997;22(3):155-169. [pmid: 9428966].
93 Jeffery RW, Wing RR, Sherwood NE, et al. Physical activity and weight loss: does prescribing higher physical activity goals improve outcome?. Am J Clin Nutr. 2003;78(4):684-689. [pmid: 14522725].
94 Johnson SB. Methodological issues in diabetes research. Measuring adherence. [Review]. Diabetes Care. 1992;15(11):1658-1667. [pmid: 1468298].
95 Kalten MR, Ardito DA, Cimino C, et al. A Web-accessible core weight management program. Diabetes Educ. 2000;26(6):929-936. [pmid: 11912805].
96 Kaplan R, Wilson D, Heitzmann C, et al. Randomized trial evaluates behavioral interventions in type-II diabetes mellitus. Diabetes. 1983;32:A169.
97 Kaplan RM, Chadwick MW, Schimmel LE. Social learning intervention to promote metabolic control in type I diabetes mellitus: pilot experiment results. Diabetes Care. 1985;8(2):152-155. [pmid: 3996172].
98 Kaplan RM, Hartwell SL, Wilson DK, et al. Effects of diet and exercise interventions on control and quality of life in non-insulin-dependent diabetes mellitus. J Gen Int Med. 1987;2(4):220-228.
99 Keen H. Normoglycaemic re-entry and diabetic complications. [Review]. Diabetic Med. 1984;1(2):85-87. [pmid: 6242792].
100 Kenardy J, Mensch M, Bowen K, et al. Group therapy for binge eating in Type 2 diabetes: a randomized trial. Diabetic Med. 2002;19(3):234-239. [pmid: 12162246].
101 Keyserling TC, Ammerman AS, Samuel-Hodge CD, et al. A diabetes management program for African American women with type 2 diabetes. Diabetes Educ. 2000;26(5):796-805. [pmid: 11140007].
102 Kingery PM, Glasgow RE. Self-efficacy and outcome expectations in the self-regulation of non-insulin dependent diabetes mellitus. Health Educ. 1989;20(7):13-19. [pmid: 2516067].
103 Kinsley BT, Weinger K, Bajaj M, et al. Blood glucose awareness training and epinephrine responses to hypoglycemia during intensive treatment in type 1 diabetes. Diabetes Care. 1999;22(7):1022-1028. [pmid: 10388961].
104 Kirk AF, Higgins LA, Hughes AR, et al. A randomized, controlled trial to study the effect of exercise consultation on the promotion of physical activity in people with Type 2 diabetes: a pilot study. Diabetic Med. 2001;18(11):877-882. [pmid: 11703431].
105 Koev DJ, Tankova TI, Kozlovski PG. Effect of structured group education on glycemic control and hypoglycemia in insulin-treated patients. Diabetes Care. 2003;26(1):251. [pmid: 12502698].
106 Korhonen T, Huttunen JK, Aro A, et al. A controlled trial on the effects of patient education in the treatment of insulin-dependent diabetes. Diabetes Care. 1983;6(3):256-261. [pmid: 6347578].
107 Korhonen T, Uusitupa M, Aro A, et al. Efficacy of dietary instructions in newly diagnosed non-insulin-dependent diabetic patients. Comparison of two different patient education regimens. Acta Med Scand. 1987;222(4):323-331. [pmid: 3425385].
108 Laitinen JH, Ahola IE, Sarkkinen ES, et al. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1993;93(3):276-283. [pmid: 8382712].
109 Lammers CA, Naliboff BD, Straatmeyer AJ. The effects of progressive relaxation on stress and diabetic control. Behav Res Ther. 1984;22(6):641-650. [pmid: 6393946].
110 Lamparski DM, Wing RR. Blood glucose discrimination training in patients with type II diabetes. Biofeedback Self Regulation. 1989;14(3):195-206. [pmid: 2597711].
111 Landis B, Jovanovic L, Landis E, et al. Effect of stress reduction on daily glucose range in previously stabilized insulin-dependent diabetic patients. Diabetes Care. 1985;8(6):624-626. [pmid: 3908030].
112 Lane JD, McCaskill CC, Ross SL, et al. Relaxation training for NIDDM. Predicting who may benefit. Diabetes Care. 1993;16(8):1087-1094. [pmid: 8375238].
113 Lean M, Anderson A. Clinical strategies for obesity management. Diabetic Med. 1988;5(6):515-518. [pmid: 2974772].
114 Lemozy-Cadroy S, Crognier S, Gourdy P, et al. Intensified treatment of type 1 diabetes: prospective evaluation at one year of a therapeutic patient education programme. Diabetes Metab. 2002;28(4 Pt 1):287-294. [pmid: 12442066].
115 Levenson D. Stress management helps control glucose in type 2 diabetics. Rep Med Guidelines Outcomes Res. 2002;13(1):5-7.
116 Levetan CS, Dawn KR, Robbins DC, et al. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. 2002;25(1):2-8. [pmid: 11772893].
117 Ligtenberg PC, Godaert GL, Hillenaar EF, et al. Influence of a physical training program on psychological well-being in elderly type 2 diabetes patients. Psychological well-being, physical training, and type 2 diabetes. Diabetes Care. 1998;21(12):2196-2197. [pmid: 9839122].
118 Little RR, Wiedmeyer HM, England JD, et al. Interlaboratory comparison of glycohemoglobin results: College of American Pathologists Survey data. Clin Chem. 1991;37(10 Pt 1):1725-1729. [pmid: 1914172].
119 Lorenz RA, Bubb J, Davis D, et al. Changing behavior. Practical lessons from the diabetes control and complications trial. Diabetes Care. 1996;19(6):648-652. [pmid: 8725866].
120 Lustman PJ, Freedland KE, Griffith LS, et al. Predicting response to cognitive behavior therapy of depression in type 2 diabetes. Gen Hosp Psych. 1998;20(5):302-306.
121 Lustman PJ, Griffith LS, Freedland KE, et al. Cognitive behavior therapy for depression in type 2 diabetes mellitus. A randomized, controlled trial. Ann Int Med. 1998;129(8):613-621. [pmid: 9786808].
122 Manning RM, Jung RT, Leese GP, et al. The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabetic Med. 1995;12(5):409-415. [pmid: 7648803].
123 Manning RM, Jung RT, Leese GP, et al. The comparison of four weight reduction strategies aimed at overweight patients with diabetes mellitus: four-year follow-up. Diabetic Med. 1998;15(6):497-502. [pmid: 9632125].
124 Maxwell AE, Hunt IF, Bush MA. Effects of a social support group, as an adjunct to diabetes training, on metabolic control and psychosocial outcomes. Diabetes Educ. 1992;18(4):303-309. [pmid: 1628531].
125 Mayer-Davis EJ, D'Antonio A, Martin M, et al. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds Off with Empowerment (POWER). Fam Comm Health. 2001;24(2):27-35.
126 Mazzuca SA, Moorman NH, Wheeler ML, et al. The diabetes education study: a controlled trial of the effects of diabetes patient education. Diabetes Care. 1986;9(1):1-10. [pmid: 3948638].
127 Mazzuca SA, Vinicor F, Cohen SJ, et al. The Diabetes Education Study: a controlled trial of the effects of intensive instruction of internal medicine residents on the management of diabetes mellitus. J Gen Int Med. 1988;3(1):1-8.
128 McCulloch DK, Glasgow RE, Hampson SE, et al. A systematic approach to diabetes management in the post-DCCT era. Diabetes Care. 1994;17(7):765-769. [pmid: 7924791].
129 McGrady A, Bailey BK, Good MP. Controlled study of biofeedback-assisted relaxation in type I diabetes. Diabetes Care. 1991;14(5):360-365. [pmid: 2060447].
130 McGrady A, Horner J. Role of mood in outcome of biofeedback assisted relaxation therapy in insulin dependent diabetes mellitus. Appl Psychophysiol Biofeedback. 1999;24(1):79-88. [pmid: 10553485].
131 McKay HG, King D, Eakin EG, et al. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care. 2001;24(8):1328-1334. [pmid: 11473065].
132 McKay HG, King D, Eakin EG, et al. The diabetes network internet-based physical activity intervention: a randomized pilot study. Diabetes Care. 2001;24(8):1328-1334. [pmid: 11473065].
133 McNabb W, Quinn M, Kerver J, et al. The PATHWAYS church-based weight loss program for urban African-American women at risk for diabetes. Diabetes Care. 1997;20(10):1518-1523. [pmid: 9314627].
134 Mensink M, Feskens EJ, Saris WH, et al. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): preliminary results after one year. Internat J Obesity Related Metabol Dis. 2003;27(3):377-384.
135 Miller CK, Edwards L, Kissling G, et al. Nutrition education improves metabolic outcomes among older adults with diabetes mellitus: results from a randomized controlled trial. Prev Med. 2002;34(2):252-259. [pmid: 11817922].
136 Miller CK, Edwards L, Kissling G, et al. Evaluation of a theory-based nutrition intervention for older adults with diabetes mellitus. J Am Diet Assoc. 2002;102(8):1069-1081. [pmid: 12171451].
137 Narayan KM, Hoskin M, Kozak D, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabetic Med. 1998;15(1):66-72. [pmid: 9472866].
138 Nordfeldt S, Johansson C, Carlsson E, et al. Prevention of severe hypoglycaemia in type I diabetes: a randomised controlled population study. Arch Dis Child. 2003;88(3):240-245. [pmid: 12598392].
139 Norris SL, Engelgau MM, Narayan KM. Effectiveness of self-management training in type-2 diabetes: a systematic review of randomized controlled trials. Diabetes Care. 2001;24(3):561-587. [pmid: 11289485].
140 Norris SL, Lau J, Smith SJ, et al. Self-management education for adults with type 2 diabetes: a meta-analysis of the effect on glycemic control. Diabetes Care. 2002;25(7):1159-1171. [pmid: 12087014].
141 Oh JA, Kim HS, Yoon KH, et al. A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J. 2003;44(1):1-8. [pmid: 12619168].
142 Padgett D, Mumford E, Hynes M, et al. Meta-analysis of the effects of educational and psychosocial interventions on management of diabetes mellitus. J Clin Epidemiol. 1988;41(10):1007-1030. [pmid: 3193136].
143 Padgett D, Mumford E, Hynes M, et al. Meta-analysis of the effects of educational and psychosocial interventions on management of diabetes mellitus. J Clin Epidemiol. 1988;41(10):1007-1030. [pmid: 3193136].
144 Page SR, Tattersall RB. How to achieve optimal diabetic control in patients with insulindependent diabetes. [Review]. Postgrad Med J. 1994;70(828):675-681. [pmid: 7831159].
145 Parchman ML, Arambula-Solomon TG, Noel PH, et al. Stage of change advancement for diabetes self-management behaviors and glucose control. Diabetes Educ. 2003;29(1):128-134. [pmid: 12632691].
146 Pascale RW, Wing RR, Blair EH, et al. The effect of weight loss on change in waist-to-hip ratio in patients with type II diabetes. Internat J Obesity Related Metabol Dis. 1992;16(1):59-65.
147 Pascale RW, Wing RR, Butler BA, et al. Effects of a behavioral weight loss program stressing calorie restriction versus calorie plus fat restriction in obese individuals with NIDDM or a family history of diabetes. Diabetes Care. 1995;18(9):1241-1248. [pmid: 8612437].
148 Perry TL, Mann JI, Lewis-Barned NJ, et al. Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). Eur J Clin Nutr. 1997;51(11):757-763. [pmid: 9368810].
149 Piette JD. Perceived access problems among patients with diabetes in two public systems of care. J Gen Int Med. 2000;15(11):797-804.
150 Piette JD, Weinberger M, Kraemer FB, et al. Impact of automated calls with nurse follow-up on diabetes treatment outcomes in a Department of Veterans Affairs Health Care System: a randomized controlled trial. Diabetes Care. 2001;24(2):202-208. [pmid: 11213866].
151 Piette JD, Weinberger M, McPhee SJ. The effect of automated calls with telephone nurse follow-up on patient-centered outcomes of diabetes care: a randomized, controlled trial. Med Care. 2000;38(2):218-230. [pmid: 10659695].
152 Piette JD, Weinberger M, McPhee SJ, et al. Do automated calls with nurse follow-up improve self-care and glycemic control among vulnerable patients with diabetes?. Am J Med. 2000;108(1):20-27. [pmid: 11059437].
153 Pohl SL, Gonder-Frederick L, Cox DJ, et al. Self-measurement of blood glucose concentration: clinical significance of patient-generated measurements. Diabetes Care. 1985;8(6):617-619. [pmid: 4075950].
154 Polley BA, Wing RR, Sims CJ. Randomized controlled trial to prevent excessive weight gain in pregnant women. Internat J Obesity Related Metabol Dis. 2002;26(11):1494-1502.
155 Rabkin SW, Boyko E, Wilson A, et al. A randomized clinical trial comparing behavior modification and individual counseling in the nutritional therapy of non-insulin-dependent diabetes mellitus: comparison of the effect on blood sugar, body weight, and serum lipids. Diabetes Care. 1983;6(1):50-56. [pmid: 6341015].
156 Raz I, Soskolne V, Stein P. Influence of small-group education sessions on glucose homeostasis in NIDDM. Diabetes Care. 1988;11(1):67-71. [pmid: 3338379].
157 Reyle LS, Thomas RK, Dew PS. Establishing a new diabetes service on the basis of health services research. Diabetes Educ. 1989;15(3):268-271. [pmid: 2714195].
158 Rickheim PL, Weaver TW, Flader JL, et al. Assessment of group versus individual diabetes education: a randomized study. Diabetes Care. 2002;25(2):269-274. [pmid: 11815494].
159 Ridgeway NA, Harvill DR, Harvill LM, et al. Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. Southern Med J. 1999;92(7):667-672. [pmid: 10414474].
160 Rost KM, Flavin KS, Cole K, et al. Change in metabolic control and functional status after hospitalization. Impact of patient activation intervention in diabetic patients. Diabetes Care. 1991;14(10):881-889. [pmid: 1773686].
161 Roter DL, Hall JA, Merisca R, et al. Effectiveness of interventions to improve patient compliance: a meta-analysis. Med Care. 1998;36(8):1138-1161. [pmid: 9708588].
162 Rubin RR, Peyrot M. Psychosocial problems and interventions in diabetes. A review of the literature. [Review]. Diabetes Care. 1992;15(11):1640-1657. [pmid: 1468297].
163 Rubin RR, Peyrot M. Psychological issues and treatments for people with diabetes. [Review]. J Clin Psychol. 2001;57(4):457-478. [pmid: 11255202].
164 Sadur CN, Moline N, Costa M, et al. Diabetes management in a health maintenance organization. Efficacy of care management using cluster visits. Diabetes Care. 1999;22(12):2011-2017. [pmid: 10587835].
165 Sarkadi A, Rosenqvist U. Field test of a group education program for type 2 diabetes: measures and predictors of success on individual and group levels. Pat Educ Counsel. 2001;44(2):129-139.
166 Sawicki PT, Didjurgeit U, Muhlhauser I, et al. Behaviour therapy versus doctor's antismoking advice in diabetic patients. J Int Med. 1993;234(4):407-409.
167 Schlenk EA, Boehm S. Behaviors in type II diabetes during contingency contracting. Appl Nurs Res. 1998;11(2):77-83. [pmid: 9627434].
168 Sidorov J, Shull R, Tomcavage J, et al. Does diabetes disease management save money and improve outcomes? A report of simultaneous short-term savings and quality improvement associated with a health maintenance organization-sponsored disease management program among patients fulfilling health employer data and information set criteria. Diabetes Care. 2002;25(4):684-689. [pmid: 11919125].
169 Smith DE, Heckemeyer CM, Kratt PP, et al. Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care. 1997;20(1):52-54. [pmid: 9028693].
170 Smith DM, Weinberger M, Katz BP. A controlled trial to increase office visits and reduce hospitalizations of diabetic patients. J Gen Int Med. 1987;2(4):232-238.
171 Snoek FJ, Skinner TC. Psychological counselling in problematic diabetes: does it help? [Review]. Diabetic Med. 2002;19(4):265-273. [pmid: 11942996].
172 Snoek FJ, van der Ven NC, Lubach CH, et al. Effects of cognitive behavioural group training (CBGT) in adult patients with poorly controlled insulin-dependent (type 1) diabetes: a pilot study. Pat Educ Counsel. 2001;45(2):143-148.
173 Spiess K, Sachs G, Pietschmann P, et al. A program to reduce onset distress in unselected type I diabetic patients: effects on psychological variables and metabolic control. Eur J Endocrinol. 1995;132(5):580-586. [pmid: 7749498].
174 Sundelin J, Forsander G, Mattson SE. Family-oriented support at the onset of diabetes mellitus: a comparison of two group conditions during 2 years following diagnosis. Acta Paed. 1996;85(1):49-55.
175 Surwit RS, Feinglos MN. The effects of relaxations on glucose tolerance in non-insulindependent diabetes. Diabetes Care. 1983;6(2):176-179. [pmid: 6343022].
176 Surwit RS, van Tilburg MA, Zucker N, et al. Stress management improves long-term glycemic control in type 2 diabetes. Diabetes Care. 2002;25(1):30-34. [pmid: 11772897].
177 Swinburn BA, Metcalf PA, Ley SJ. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24(4):619-624. [pmid: 11315819].
178 Tate DF, Jackvony EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. JAMA. 2003;289(14):1833-1836. [pmid: 12684363].
179 Tate DF, Wing RR, Winett RA. Using Internet technology to deliver a behavioral weight loss program. JAMA. 2001;285(9):1172-1177. [pmid: 11231746].
180 Tattersall RB, McCulloch DK, Aveline M. Group therapy in the treatment of diabetes. [Review]. Diabetes Care. 1985;8(2):180-188. [pmid: 3888565].
181 Terent A, Hagfall O, Cederholm U. The effect of education and self-monitoring of blood glucose on glycosylated hemoglobin in type I diabetes. A controlled 18-month trial in a representative population. Acta Med Scand. 1985;217(1):47-53. [pmid: 3883704].
182 Trento M, Passera P, Bajardi M, et al. Lifestyle intervention by group care prevents deterioration of Type II diabetes: a 4-year randomized controlled clinical trial. Diabetologia. 2002;45(9):1231-1239. [pmid: 12242455].
183 Trento M, Passera P, Tomalino M, et al. Therapeutic group education in the follow-up of patients with non-insulin treated, non-insulin dependent diabetes mellitus. Diabetes Metab Clin Exp. 1998;11:212-216.
184 Tsujiuchi T, Kumano H, Yoshiuchi K, et al. The effect of Qi-gong relaxation exercise on the control of type 2 diabetes mellitus: a randomized controlled trial. Diabetes Care. 2002;25(1):241-242. [pmid: 11772923].
185 Tu KS, McDaniel G, Gay JT. Diabetes self-care knowledge, behaviors, and metabolic control of older adults—the effect of a posteducational follow-up program. Diabetes Educ. 1993;19(1):25-30. [pmid: 8458295].
186 Turnin MC, Beddok RH, Clottes JP, et al. Telematic expert system Diabeto. New tool for diet self-monitoring for diabetic patients. Diabetes Care. 1992;15(2):204-212. [pmid: 1547677].
187 Valk GD, Kriegsman DM, Assendelft WJ. Patient education for preventing diabetic foot ulceration. [Review]. Cochrane Database System Rev. 2001;(4):CD001488. [pmid: 11687114].
188 Vanninen E, Uusitupa M, Siitonen O, et al. Habitual physical activity, aerobic capacity and metabolic control in patients with newly-diagnosed type 2 (non-insulin-dependent) diabetes mellitus: effect of 1-year diet and exercise intervention. Diabetologia. 1992;35(4):340-346. [pmid: 1516762].
189 Warren-Boulton E, Greenberg R, Lising M, et al. An update on primary care management of type 2 diabetes. [Review]. Nurse Pract. 1999;24(12):14-16. 19. 20. 23–4 passim; quiz 32–3. [pmid: 10635516].
190 Wdowik MJ, Kendall PA, Harris MA, et al. Development and evaluation of an intervention program: "Control on Campus". Diabetes Educ. 2000;26(1):95-104. [pmid: 10776101].
191 Weinberger M, Kirkman MS, Samsa GP, et al. The relationship between glycemic control and health-related quality of life in patients with non-insulin-dependent diabetes mellitus. Med Care. 1994;32(12):1173-1181. [pmid: 7967857].
192 Weinberger M, Kirkman MS, Samsa GP, et al. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Int Med. 1995;10(2):59-66.
193 Werdier D, Jesdinsky HJ, Helmich P. A randomized, controlled study on the effect of diabetes counseling in the offices of 12 general practitioners. Revue d Epidemiologie Et De Sante Publique. 1984;32(3–4):225-229. [pmid: 6522737].
194 White N, Carnahan J, Nugent CA, et al. Management of obese patients with diabetes mellitus: comparison of advice education with group management. Diabetes Care. 1986;9(5):490-496. [pmid: 3769719].
195 Wierenga ME. Life-style modification for weight control to improve diabetes health status. Pat Educ Counsel. 1994;23(1):33-40.
196 Williams KV, Mullen M, Lang W, et al. Weight loss and leptin changes in individuals with type 2 diabetes. Obesity Res. 1999;7(2):155-163.
197 Williams KV, Mullen ML, Kelley DE, et al. The effect of short periods of caloric restriction on weight loss and glycemic control in type 2 diabetes. Diabetes Care. 1998;21(1):2-8. [pmid: 9538962].
198 Wing RR. Insulin sensitivity as a predictor of weight regain. Obesity Res. 1997;5(1):24-29.
199 Wing RR, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19(5):409-413. [pmid: 8732700].
200 Wing RR, Blair E, Marcus M, et al. Year-long weight loss treatment for obese patients with type II diabetes: does including an intermittent very-low-calorie diet improve outcome?. Am J Med. 1994;97(4):354-362. [pmid: 7942937].
201 Wing RR, Blair EH, Bononi P, et al. Caloric restriction per se is a significant factor in improvements in glycemic control and insulin sensitivity during weight loss in obese NIDDM patients. Diabetes Care. 1994;17(1):30-36. [pmid: 8112186].
202 Wing RR, Epstein LH, Nowalk MP, et al. Behavior change, weight loss, and physiological improvements in type II diabetic patients. J Consult Clin Psychol. 1985;53(1):111-122. [pmid: 3980816].
203 Wing RR, Epstein LH, Nowalk MP, et al. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. Am J Med. 1986;81(5):830-836. [pmid: 3535493].
204 Wing RR, Goldstein MG, Acton KJ, et al. Behavioral science research in diabetes: lifestyle changes related to obesity, eating behavior, and physical activity. [Review]. Diabetes Care. 2001;24(1):117-123. [pmid: 11194216].
205 Wing RR, Koeske R, Epstein LH, et al. Long-term effects of modest weight loss in type II diabetic patients. Arch Int Med. 1987;147(10):1749-1753. [pmid: 3310940].
206 Wing RR, Marcus MD, Blair EH, et al. Psychological responses of obese type II diabetic subjects to very-low-calorie diet. Diabetes Care. 1991;14(7):596-599. [pmid: 1914801].
207 Wing RR, Marcus MD, Epstein LH, et al. A "family-based" approach to the treatment of obese type II diabetic patients. J Consult Clin Psychol. 1991;59(1):156-162. [pmid: 2002132].
208 Wing RR, Marcus MD, Salata R, et al. Effects of a very-low-calorie diet on long-term glycemic control in obese type 2 diabetic subjects. Arch Int Med. 1991;151(7):1334-1340. [pmid: 2064484].