# Methods

## Key Questions Addressed

We address four Key Questions in this report. These questions are presented below:

1. What are the patient inclusion and exclusion criteria used in studies of decompression therapy?
2. What are the efficacy or effectiveness outcomes measured in studies of decompression therapy? Are the efficacy/effectiveness outcomes measured in studies of decompression therapy comparable to those used in studies of other non-surgical modalities for chronic low back pain due to a herniated disc or degenerative disc disease?
3. Is decompression therapy a safe and effective treatment of chronic low back pain due to herniated disc or degenerative disc disease?
  a. Do patients with chronic low back pain (due to a herniated disc or degenerative disc disease) who are treated with decompression therapy have more, less, or the same level of pain relief than patients who are treated with other therapies?
  b. Do patients treated with decompression therapy for chronic low back pain due to a herniated disc or degenerative disc disease utilize more, less, or the same number of adjunct/chronic therapies, (e.g., medications, bracing) than patients treated with other therapies?
  c. Do patients treated with decompression therapy for chronic low back pain due to a herniated disc or degenerative disc disease return to work more quickly than patients treated with other therapy?
  d. If the therapy is effective, what is the duration of relief achieved?
  e. If the therapy is effective, what are the patient characteristics/indications of those for whom it appears to work? Is the therapy effective for the Medicare population (over 65 years of age)?
  f. If it works, which, if any, particular decompression protocol provides the most pain relief?
4. What complications, harms, and adverse events associated with decompression therapy have been reported?
  a. Do conditions prevalent in the older Medicare population (such as osteoporosis, etc.) increase the risk of adverse events with decompression therapy?

The four Key questions are depicted in the Figure as numbers within a circle.

Figure 1 Analytical Framework

Patient population. Intervention. Health outcomes. Health systems outcomes. Individual with chronic low back pain due to herniated disc or degenerative disc disease. Decompression therapy vs. other therapy. Pain - Return to work, Return to normal activities, Reduced use of analgesics. Costs - Surgeries avoided. Adverse Events. Outcome Outcome evaluated. Outcome Outcome not evaluated. Key question number

## Study Inclusion/Exclusion Criteria

We selected the studies that we consider in this report using a priori inclusion criteria. As mentioned above, arriving at these criteria before beginning the analysis is one way of reducing bias. We developed different inclusion criteria for each question that this report addresses.

### General Inclusion/Exclusion Criteria

The following inclusion/exclusion/criteria were general to all five Key Questions:

1. Studies must have been published in English. Moher et al. have demonstrated that exclusion of non-English language studies from meta-analyses has little impact on the conclusions drawn.(35) Juni et al found that non-English studies typically were of lower methodological quality and that excluding them had little effect on effect size estimates in the majority of meta-analyses they examined.(36) Although we recognize that there may be situations in which exclusion of non-English studies could lead to bias, we believe that it is insufficiently likely that we cannot justify the time and cost of translations to identify studies of acceptable quality for inclusion in our reviews.
2. Studies must have addressed one of the Key Questions.
3. Studies must have been published as full journal articles (no meeting abstracts). Meeting abstracts generally have insufficient description of methods to allow assessment of quality, and the reported results often contain discrepancies with results presented in later peer-reviewed publication of the same study.(37–40)
4. If the same study is reported in multiple publications, only the most recent publication will be included. This serves to avoid duplication of data.

### Inclusion/Exclusion Criteria Specific to Key Question 1

The following inclusion/exclusion/criteria were specific to Key Question 1:

- Any article that provides the inclusion/exclusion criteria for a unique study of the efficacy/effectiveness and safety of vertebral axial decompression therapy.
  Study design has no impact on the validity of its inclusion/exclusion criteria. Consequently, we did not exclude any articles based on the design of the study that they described.

### Inclusion/Exclusion Criteria Specific to Key Question 2

The following inclusion/exclusion/criteria were specific to Key Question 2:

- Systematic reviews of other non-surgical treatments for chronic low back pain due to herniated disc or degenerative disc disease published after January 1^st^, 2004, will be used to describe outcomes typically reported by trials of non-surgical therapy for these conditions.

### Inclusion/Exclusion Criteria Specific to Key Question 3

The following inclusion/exclusion/criteria were specific to Key Question 3:

- Article must describe a study that directly compared decompression therapy to other treatments or different decompressive therapy dosage regimes.
  Although it is possible to compare different treatments when one group of studies reports the results obtained with one treatment, and another group of studies reports the results of another treatment, the results of such indirect comparisons should be viewed with caution. Several methodologists have shown that the difference in treatment effectiveness estimated using indirect methods is greater than the difference observed in trials that directly compare two treatments.(41,42)
- Only outcomes within a study that had a score of 5.0 or greater on our quality scale were included.
  Outcomes with scores of 4.9 or less are likely to be biased. We do not consider these reliable sources of information. Because each outcome in a study is given a quality score, some outcomes within a study may fall below 5.0 and be excluded, while other outcomes may score better than 5.0 and be included. It is possible for a study to be “included” in the report because it met the other inclusion criteria, and yet have all of its data excluded from analysis due to quality reasons.
- Only studies with at least 10 patients in each treatment were included.
  The results of studies with very small patient groups are often not applicable to the general population.

### Inclusion/Exclusion Criteria Specific to Key Question 4

The following inclusion/exclusion/criteria were specific to Key Question 4:

- A study of any design that meets the general inclusion criteria for this report (including case series, case reports, and reports from ECRI’s Health Device Alerts database) were included.
  Although uncontrolled studies cannot be used to determine causality or to estimate frequency of adverse events, they can be used to generate a list of adverse events possibly attributable to the device.

## Literature Searches

One characteristic of a good technology assessment is a systematic and comprehensive search for information. Such searches distinguish systematic reviews from traditional literature reviews. Traditional reviews use a less rigorous approach to identifying and obtaining literature and allow a reviewer to include only articles that agree with a particular perspective, and to ignore articles that do not. Our approach precludes this potential reviewer bias because we obtained and included articles according to explicitly determined a priori criteria. This was particularly important for Key Question 3, the assessment of efficacy. We discuss articles that we included in the Synthesis of Results section.

### Electronic Database Searches

We searched 17 external and internal databases, including PubMed and Embase, for clinical trials on the use of decompression therapy to treat lower back pain. We also examined the bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature includes reports and studies produced by local government agencies, private organizations, educational facilities, and corporations that do not appear in peer-reviewed journals.) We examined gray literature sources to identify relevant information such as reference listings and product information to address Question 1 and peer-reviewed and gray literature, as well as ECRI databases such as the Health Devices Alert Database to identify adverse events for Question 4. However, we only utilize published, peer-reviewed literature in this report to address Questions 2 and 3. All of the databases and the detailed search strategies used in this report are presented in Appendix A.

## Identification of Evidence Bases

The selection process used to identify the articles that comprise the evidence base for the key questions addressed in this report is presented in Figure 2. Our searches identified ten articles that potentially addressed Key Questions 1 through 4. Of these ten articles, we retrieved seven. Three additional studies(8–10) were brought to our attention by reviewers, for a total of ten included studies (Table 3). These three additional studies did not meet criteria for Key Question 3 as they were not comparative studies and two had fewer than 10 patients, but we did review them for information relevant to the other Key Questions. Eight included articles addressed Key Question 1, nine included articles addressed Key Questions 2, three included articles addressed Key Question 3, and all ten articles were reviewed for adverse events, Key Question 4.

Figure 2 Summary of Article Selection Process

10 Citations identified through searches. 3 Abstracts did not meet retrieval criteria. 7 articles retrieved 10 articles included in report. No additional articles excluded. 3 articles identified by reviewers suitable for KQ 1,2, and 4. 8 articles address Key Question 1. 9 articles address Key Question 2. 3 articles address Key Question 3. 10 articles address Key Question 4

Table 3 Evidence Base

Reference | Year | Institution | Country | Key Question Addressed
Reference | Year | Institution | Country | 1 | 2 | 3 | 4
Deen et al.(2) | 2003 | Mayo Clinic, Jacksonville, FL | USA | | | | ✓
Gose et al.(5) | 1998 | Coosa Medical Group, Rome, Georgia | USA | ✓ | ✓ | | ✓
MSAC(4) | 2001 | Medical Services Advisory Committee (Gov’t) | Australia | | ✓ | | ✓
Naguszewski et al.(9) | 2001 | Coosa Medical Group, GA University of Illinois, IL | USA | | ✓ | | ✓
Ramos(1) | 2004 | University of Texas | USA | | ✓ | ✓^*^ | ✓
Ramos and Martin(8) | 1994 | Rio Grande Regional Hospital; University of Texas, TX | USA | | ✓ | | ✓
Shealy et al.(10) | 2005 | Holos University and North American Medical Corporation | USA | ✓ | ✓ | | ✓
Shealy and Borgmeyer(6) | 1997 | Shealy Institute for Comprehensive Health Care and Clinical Research | USA | ✓ | ✓ | ✓ | ✓
Sherry et al.(3) | 2001 | Sydney University; VAX-D Australasia Pty. Ltd | Australia | ✓ | ✓ | ✓ | ✓
Tilaro and Miskovich(7) | 1999 | Advanced Spinal Institute, Ogden, UT | USA | ✓ | ✓ | | ✓
Number of articles included in Evidence Base | | | | 8 | 9 | 3 | 10

* Outcome data not considered when addressing Key Question 3 because of an unacceptably high potential for bias.

## Evaluating the Strength of the Evidence

We used the ECRI strength-of-evidence system to evaluate the stability and strength of a body of literature (shown in Appendix B). This system considers numerous components of the evidence, including the internal validity of the trials, the size of the evidence base, consistency and robustness of trial results, and magnitude of the effect size. The system outputs two ratings. One is a stability rating (high, moderate, low, unstable) for a quantitative estimate addressing the question “How well does it work?” The other is a strength rating (strong, moderate, weak, inconclusive) for the evidence about the qualitative question “Does it work?” This distinction allows an evidence base to be considered weak in terms of the quantitative estimate of effect (e.g., if estimates vary widely among trials) but strong or moderate with respect to the qualitative conclusion (e.g., if all trials nevertheless demonstrate the same direction of effect). The system also employs a priori judgments, meta-analyses, and sensitivity analyses to provide sound bases for evidence ratings. Interpretations of the terms that define the strength of evidence (strong evidence, moderate evidence, weak evidence, and inconclusive evidence) and stability ratings (high stability, moderate stability, low stability or unstable) are presented in Table 4.(43)

Table 4 Definitions of Strength and Stability of Evidence

Strength of Evidence Rating | Interpretation
Qualitative Conclusion (Direction of Effect)
Strong Evidence | Evidence supporting the qualitative conclusion is convincing, making it highly unlikely that new evidence will lead to a change in this conclusion.
Moderate Evidence | Evidence supporting the qualitative conclusion is somewhat convincing. However, a small chance exists that new evidence will overturn or strengthen our conclusion. Regular monitoring of the relevant literature is recommended at this time.
Weak Evidence | Although some evidence supports the qualitative conclusion, this evidence is tentative and perishable. A reasonable chance exists that new evidence will overturn or strengthen our conclusions. Frequent monitoring of the relevant literature is recommended at this time.
Inconclusive | The available evidence that exists is not of sufficient strength to warrant drawing an evidence-based conclusion. Frequent monitoring of the relevant literature is recommended at this time.
Quantitative Conclusion (Magnitude of Effect)
High Stability | The estimate of effect size in the conclusion is stable, making it highly unlikely that the magnitude of this estimate will substantially change as a result of the publication of new evidence.
Moderate Stability | The estimate of effect size in the conclusion is somewhat stable. However, a small chance exists that the magnitude of this estimate will substantially change as a result of the publication of new evidence. Regular monitoring of the relevant literature is recommended at this time.
Low Stability | The estimate of effect size in the conclusion is likely to be unstable. A reasonable chance exists that the magnitude of this estimate will substantially change as a result of the publication of new evidence. Frequent monitoring of the relevant literature is recommended at this time.
Unstable | Estimates of the effect size are too unstable to allow a quantitative conclusion to be drawn at this time. Frequent monitoring of the relevant literature is recommended.

The 10 decision points that comprise the ECRI strength-of-evidence system address five general aspects of the evidence (domains): quality, quantity, consistency, robustness, and magnitude of treatment effect. Quality refers to the degree of potential bias in the design or conduct of studies. Quantity refers to the number of studies and the number of patients enrolled in the studies. Consistency addresses the degree of agreement among the results of available studies. Robustness refers to the degree to which the findings are susceptible to being overturned by future studies. Magnitude of treatment effect concerns the quantitative amount of benefit (or harm) that patients experience after treatment. The ECRI strength-of-evidence system includes all five of these aspects when assessing the strength of the evidence (see Appendix B).

We apply each kind of rating to the body of evidence that addresses each outcome, not to individual studies. We also rate on an outcome-by-outcome basis. Four primary factors determine our ratings for both strength and stability; the quality, quantity, robustness, and consistency of the evidence. Under certain circumstances, the size of the treatment’s effect, and whether mega-trials are available also influence our ratings of the evidence underlying qualitative conclusions.

## Statistical Methods

The current evidence base was too small to allow us to employ statistical methods such as meta-analysis.

## Characteristics of Included Studies

Information on study characteristics is presented in Table 5. We present more complete details of these studies (study design details, information on enrolled patients, outcome data, and other relevant information) in the evidence tables that comprise Appendix D.

Table 5 Characteristics of Included Studies

Reference | Year | N | Study Design/Purpose | Interventions
Medical Services Advisory Committee (MSAC)(4) | 2001 | NA | Design: Technology assessment of vertebral axial decompression therapy for chronic low back pain which included a systematic review of published and unpublished studies for evidence of efficacy and adverse events Purpose: To provide evidence assessment for health care financing decisions for Commonwealth of Australia | Treatment Intervention: VAX-D device (2 published and 2 unpublished studies) Comparators: Indirect comparisons to discectomy, laminectomy and conservative therapy (NSAIDs or physical therapy)
Shealy and Borgmeyer(6) | 1997 | 25 | Design: Randomized Controlled Trial (RCT) Purpose: To evaluate the response to DRS + TENS therapy as compared to traction + TENS | Treatment Intervention: DRS System 30 minute treatment sessions; 60 seconds on, 60 seconds off; up to 30 degrees of distraction forces; 20 sessions total 30 minutes of ice and TENS applied after each session Control Intervention: Standard traction 30 minute treatment sessions; 60 seconds on, 60 seconds off; 20 sessions total; 30 minutes of ice and TENS applied after each session Other intervention: All patients were given a TENS unit for continuous home use, and were instructed and supervised in a limbering/strengthening exercise program
Sherry et al.(3) | 2001 | 22 | Design: RCT Purpose: To evaluate the response to VAX-D therapy when compared to TENS and medical management | Treatment Intervention: VAX-D device Prone position; 30 minute sessions; 15 cycles per session Five sessions per week for 4 weeks, then once per week for 4 weeks Control Intervention: TENS Prone position; 30 minute sessions; daily sessions for 20 days, then once a week for 4 weeks Other Intervention: No physical therapy, steroid injection, or other treatments allowed during the trial. Non-narcotic pain relievers and anti-inflammatory medications could be taken if necessary
Ramos(1) | 2004 | 142 | Design: Controlled trial Purpose: To evaluate the response to VAX-D therapy when compared to accelerated VAX-D therapy | Treatment Intervention: VAX-D device 30 minute sessions; 15 cycles per session Five sessions per week for a total of 20 sessions Control Intervention: VAX-D device 30 minute sessions; 15 cycles per session Five sessions per week for a total of 10 sessions Other Interventions: No exercises, stretching, or other physical therapy allowed. Pain relieving medication was allowed as necessary
Gose et al.(5) | 1998 | 778 | Design: Case series Purpose: To evaluate the response to VAX-D therapy in patients who underwent a minimum of 10 sessions | Treatment: VAX-D therapy. 30 minute sessions; 15 cycles per session
Shealy et al.(10) | 2005 | 35 | Design: Case Series Purpose: To evaluate long-term benefits of Intervertebral Differential Dynamics (IDD) Therapy® | Treatment Intervention: IDD Therapy® (utilizing the Accu-Spina device) Other Intervention: “an expanded physical therapy component,” not otherwise described
Naguszewski et al.(9) | 2001 | 7 | Design: Case Series Purpose: To use dermatomal somatosensory evoked potentials (DSSEPs) to demonstrate lumbar root decompression following VAX-D therapy | Treatment Intervention: VAX-D device Other Intervention: None reported
Ramos and Martin(8) | 1994 | 5 | Design: Case Series Purpose: To examine the effect of vertebral axial decompression on pressure in the nucleus pulposus of lumbar discs | Intervention: Individuals with a cannula introduced into the nucleus pulposus of the L4–5 intervertebral disc underwent measurement of intradiscal pressure during 5 to 8 sessions of treatment with VAX-D at varying amounts of tension.
Tilaro and Miskovich(7) | 1999 | 17 | Design: Case Series based on retrospective chart review Purpose: To determine whether VAX-D therapy decompresses nerve roots based on Current Perception Threshold (CPT) neurometer testing | Treatment Intervention: VAX-D device (3–5 sessions per week for an average of 23 total treatments). Other Intervention: No physical therapy or exercise therapy other treatments allowed during the trial. Non-narcotic pain relievers and anti-inflammatory medications could be taken if necessary
Deen et al.(2) | 2003 | 1 | Design: Case Report | Treatment Intervention: VAX-D device Other Intervention: Microdiscectomy performed for disc protrusion and migration of disc fragment which was diagnosed following VAX-D treatment

We reviewed a technology assessment prepared for the Australian Medical Services Advisory Committee (MSAC) in support of health care financing decisions.(4) Three of the studies included in this report were controlled trials: a randomized controlled trial (RCT), a controlled trial with an inappropriate (sequential) method of randomization, and one non-randomized controlled trial.(1,3,6) One included study was a case series that reported on outcomes from 778 patients who received vertebral axial decompression therapy in one of 22 centers across the United States.(5) Another case series sought to examine long-term (12-month) outcomes in a group of patients who underwent IDD Therapy® in conjunction with “an expanded physical therapy component.”(10) Three additional case series reported physiological outcomes. These included current perception threshold (CPT) as an indicator of nerve root decompression,(7) changes in intradiscal pressures during decompression therapy(8), and dermatomal somatosensory evoked potentials.(9) Finally, we included a case report describing an adverse event that occurred during vertebral axial decompression therapy.(2)