# Evidence Synthesis

## Key Question #1 What are the patient inclusion and exclusion criteria used in studies of decompression therapy?

Eight studies described their inclusion and exclusion criteria.(1,3,5–10)

### Quality of Evidence Base

Because this Key Question does not concern the causal relationship between decompression therapy and treatment outcome, an assessment of study quality is not relevant.

### Findings

We present the inclusion and (for three studies) exclusion criteria reported in the eight studies that address this Key Question in Table 6. The only inclusion/exclusion criterion consistently listed across all of the studies was that enrolled patients must have suffered from chronic low back pain related to radiographically confirmed disc degeneration or herniation. Common exclusion criteria described in the two studies reporting them were tumor, infection spinal instability and surgical implants. Other reported inclusion/exclusion criteria were unique to individual studies. Of particular relevance to the Medicare population is the fact that the two studies which included patients over the age of 65 specifically excluded patients with “severe osteoporosis.”(1,10)

Table 6 Inclusion and Exclusion Criteria in studies of Vertebral Axial Decompression Therapy

Study | Inclusion criteria | Exclusion criteria
Gose et al. 1998(5) | - Patients must have undergone at least 10 sessions of VAX-D; - Patients must have had a confirmed (through imaging studies) diagnosis of herniated disc, degenerative disc, or facet syndrome | No exclusion criteria were reported
Naguszewski et al. 2001(9) | - Patients with low back pain with referred pain in the L5 and/or S1 distribution; disc bulging or herniation on imaging study | No exclusion criteria were reported
Ramos 2004(1) | - Low back pain; - Non-progressive neurological deficits; - All patients were imaged with MRI or CT to confirm presence of discogenic disorder | - Cauda equina syndrome; - Tumor; - Infection; - Severe osteoporosis; - Fracture; - Bilateral pars defect; - Spondylolisthesis Grade 2; - Presence of surgical hardware
Ramos and Martin 1994(8) | - Patients with lumbar disc herniation confirmed by MRI and selected for Percutaneous discectomy | No exclusion criteria were reported
Shealy et al. 2004(10) | - Patients with low back pain, with/or without previous failed attempts with other treatments (acupuncture, surgery, medications, physical therapy, etc.) | - Severe osteoporosis; - Vertebral fractures; - Spondylolisthesis grade 2 or higher; - Unstable surgical conditions or surgical hardware; - Vertebral fusion within previous 6 months; - Spinal instability
Shealy and Borgmeyer 1997(6) | - Ruptured lumbar disc and/or facet arthroses; all patients underwent MRI | No exclusion criteria were reported
Sherry et al. 2001(3) | - Chronic low back pain (>3 months duration); - Associated leg pain; - Disc protrusion or herniation confirmed on CT scan or MRI; - Age 18 to 65 years; - Minimum VAS score of 2.0; - Live within 45 minutes of the clinic; - Able to give informed consent | - Osseous stenosis; - Unstable spine; - Spinal surgical implants; - Shoulder problems; - Spinal pain due to tumor, infection, or inflammatory disease; - Pregnancy; - Previous VAX-D therapy
Tilaro and Miskovich 1999(7) | - Post-hoc: Patients must have had abnormal CPT (current perception threshold) grades with sciatica, positive SLR and imaging studies correlating with observed clinical syndrome. | No exclusion criteria were reported

### Subsection Summary

The studies that addressed this question required that enrolled patients have radiographically confirmed disc degeneration or herniation or facet arthritis. Common exclusion criteria reported in the three studies reporting them were tumor, infection spinal instability and surgical implants.

## Key Question #2 What are the efficacy or effectiveness outcomes measured in studies of decompression therapy? Are the efficacy/effectiveness outcomes measured in studies of decompression therapy comparable to those used in studies of other non-surgical modalities for chronic low back pain due to a herniated disc or degenerative disc disease?

Eight included studies(1,3,5–10) and the health technology assessment(4) presented efficacy or effectiveness outcomes. The efficacy or effectiveness outcomes assessed by the eight studies are listed in Table 13 of Appendix D. No additional outcome measures were identified in the previous health technology assessment.

### Quality of Evidence Base

Because this Key Question does not concern the causal relationship between vertebral axial decompression or decompression therapy and treatment outcome, an assessment of study quality is not relevant.

### Findings

The most frequently reported outcome measures evaluated by these studies of the efficacy or effectiveness of decompression therapy were pain relief (as pre-, post- or change in pain scores) or percentage improvement in pain score (six studies), functional outcomes (three studies) and physiological outcome measures (three studies). For the studies reporting physiological measures, only one also reported a patient-oriented outcome (percent improvement in pain).(9) The physiological measures were current perception threshold (for detecting sensory changes),(7) dermatomal somatosensory evoked potentials (for detecting sensory changes)(9) and intradiscal pressure (to explore a possible mechanism for the clinical effects of VAX-D therapy).(8) The functional outcome measures included self-report of ADLs (0 – 5 scale),(1) a disability rating specific to the individual’s most affected activities (0 – 4 scale),(3) and limitation of ambulation (0 – 3 scale).(5) The study which collected patient-reported ADL information did not report the results, but incorporated the data into an overall assessment (remission, partial remission or no response), which also incorporated pain relief and return to work.

Table 13 of Appendix D lists the outcomes in the decompression studies along with those commonly assessed in studies of other non-surgical modalities for chronic low back pain due to herniated disc or degenerative disc disease.(11,21,22,44–46) A number of outcomes have been evaluated and reported by studies of these other non-surgical modalities that have not been reported by studies of decompression therapy. These include absenteeism, return to work, overall health, analgesic consumption, low back pain-related disability rates, recovery time, gait analysis, and quality of life.

### Subsection Summary

The outcomes in these studies of spinal decompression therapy also reported in studies of other non-surgical treatment options for low back pain are pain scores, pain relief and functional status. Data pertaining to a number of outcomes that are commonly reported by studies of other non-surgical treatment modalities (absenteeism, return to work, overall health, analgesic consumption, low back pain-related disability rates, recovery time, gait analysis, quality of life), are not yet available in the spinal decompression therapy literature.

## Key Question #3 Is decompression therapy an effective treatment for chronic low back pain due to herniated disc or degenerative disc disease?

Three included studies that enrolled a total of 225 patients address Key Question 3.(1,3,6) Complete study design details of these three studies are presented in Table 14 and Table 15 in Appendix D. Two of the studies evaluated the VAX-D system(1,3); the remaining study evaluated the DRS system.(6)

### Quality of Evidence Base

The results of our assessment of the quality of the studies that comprise the evidence base for Key Question 3 are presented in Table 7. Details of the quality assessment are presented in Table 16 of Appendix D.

Table 7 Results of Assessment of Study Quality

Study | Year | ECRI Quality Score (Quality category) | Notes
Ramos(1) | 2004 | 4.1 (Unacceptable) | VAX-D System Excluded from evidence base for Key Question 3 because of poor quality
Sherry et al.(3) | 2001 | 6.6 (Low Quality) | VAX-D System
Shealy and Borgmeyer(6) | 1997 | 6.6 (Low Quality) | DRS System

The study by Ramos(1) was an open (unblinded) comparative trial in which no attempt was made to ensure the patient groups were comparable at baseline. ECRI’s evaluation of the study found it to be highly susceptible to bias. Consequently, we do not consider this study further for Key Question 3.

The study by Sherry et al.(3) was an open trial in which patients were randomized by sequential order, generally considered an inappropriate method of randomization. Our assessment of the quality of this study found it to be of low quality.

The study by Shealy and Borgmeyer(6) of the DRS® system was a blinded randomized trial. Despite this, our assessment of the quality of this study found it to be of low quality. A number of factors led to this categorization. First, the method of randomization was not described in the article describing the study. This precludes one from determining whether randomization was stochastic and whether concealment of allocation to treatment groups occurred. Second, although patients were blinded to their treatment assignments, the study did not report on the success of blinding or whether unblinded investigators were involved in ascertaining patients’ ratings of their response to treatment. Third, it appears that patients’ ratings depended on their recollection of their symptoms prior to entering the study. Lastly, the authors of the study have significant financial interests in the company that manufactures the DRS® system; Dr. Shealy is the inventor of the DRS®system(47) and director of the Shealy Institute, a pain management facility which utilizes DRS® in its treatments, and Ms. Borgmeyer is a Research Coordinator at the same institute(6)

### Characteristics of Enrolled Patients

Important characteristics of the patients enrolled in the two studies that comprise the evidence base for Key Question 3 are summarized in Table 8. We present further information on the characteristics of the patients enrolled in the two included studies in Table 12 in Appendix D.

Table 8 Characteristics of Enrolled Patients (Key Question 3)

Study | Year | Mean duration of pain before entering trial | Mean age (years) and range | % older than 65 | % female | Ethnicity
Sherry et al.(3) | 2001 | All: 7.3 years (0.25 to 30) VAX-D: 8.4 years (0.25 to 30) TENS: 6.2 years (0.5 to 2.8) | All: 42 (22–57) VAX-D: 41 (27–57) TENS: 43 (27–55) | 0% | All: 47.7% VAX-D: 50.0% TENS: 45.5% | All: 90.9% white 9.1% Asian VAX-D: 90.9% white 9.1% Asian TENS: 90.9% white 9.1% Asian
Shealy and Borgmeyer(6) | 1997 | DRS system: All had symptoms of less than 1 year | Mean not reported range 31 to 63 | 0% | 30.7% | Not reported

In both included studies, enrolled patients suffered from chronic low back pain that was unresponsive to conservative treatment. As indicated below, patients in the Sherry et al. study had (on average) been symptomatic much longer than those in the Shealy and Borgmeyer study. Disc problems were confirmed by imaging studies in both studies. Patients with facet arthritis in the study by Shealy and Borgmeyer underwent MRI to rule out other pathology.(6) The enrolled patients are therefore representative of the type of patient likely to be treated by decompression therapy in the clinic. Neither study included patients over 65 years of age.

### Findings

The findings of the two low quality studies that form the evidence base for Key Question 3 are presented in Table 17 and Table 18 of Appendix D. Both studies found that the two types of decompression therapy were effective in reducing pain.

Sherry et al. compared a typical VAX-D decompression protocol in 22 patients to treatment with TENS in 22 patients. The TENS protocol used has been criticized as being suboptimal, and not a typical TENS protocol in that patients received TENS therapy for thirty minutes once daily, five days a week, rather than continuously or as needed for pain. The protocol described for each type of therapy was to provide 24 treatments (five days a week for four weeks, then once a week for four weeks). However, the VAX-D treated patients received a mean of 24.1 treatments, with a range of 18 to 36, while the TENS group received a mean of 18.0, range 10 to 24 treatments. Whether the overall duration of treatment was longer in the VAX-D group is not noted.(4)

Post-treatment VAS scores in the study by Sherry et al(3) indicate that the “evaluable” patients treated with decompression therapy had greater pain relief than patients in the control group. The difference was both statistically and clinically significant. Of note, three of four randomized patients who were not considered “evaluable” were treated with VAX-D. Two of these patients were noted after treatment to have had baseline VAS scores <2.0, and another withdrew because treatment was no longer required. One patient in the TENS group did not wish to continue treatment. In addition to reporting changes in VAS scores, Sherry et al. also reported the percentage of patients achieving at least 50% pain relief. No patients in the control group achieved this level of pain relief, as compared to 68% of patients in the decompression group who did achieve this level of pain relief. This difference is both statistically and clinically significant.

Sherry et al. also asked the participants to rate their disability on four activities most affected by their low back pain. Mean disability scores pre- and post-treatment were reported without measures of variance or tests of statistical significance. On a scale of 1 – 4, with 1 indicating complete disability and 4 representing no limitation of activity, the mean scores for the VAX-D group were 2.2 (pre-) and 2.9 (post-treatment); mean scores for the TENS group remained 2.2.(3)

Shealy and Borgmeyer(6) compared a typical DRS decompression protocol in addition to TENS to a standard traction therapy protocol in addition to TENS. They did not report changes in VAS scores, but did report the percentage of patients reporting “poor,” “good” or “excellent” improvement in symptoms. The article does not provide specific details on severity or nature of baseline symptoms or how patients’ assessments of improvement were ascertained. Patients treated with DRS decompression therapy were more likely to have excellent improvement in symptoms than patients treated with traction. However, when patients with excellent and good improvement after treatment were combined, the difference between treatment groups was not statistically significant.

### Key Question 3 a Do patients with chronic low back pain (due to herniated disc or degenerative disc disease) who are treated with decompression therapy have more, less, or the same level of pain relief than patients who are treated with other therapies?

Sherry et al. stated that after completion of VAX-D treatment, 13 of 19 (68.4%) of evaluable patients reported a successful treatment (defined as a 50% reduction in pain and any improvement in disability). Patients in the control group received TENS therapy, with none of 21 (0%) evaluable patients reporting a successful treatment. Shealy and Borgmeyer stated that 18 of 22 (81.8%) patients in the DRS therapy/TENS group reported an excellent/good treatment outcome (defined as ≥50% improvement). For patients in the traction/TENS control group this level of improvement was achieved in nine of 17 (52.9%). However, no evidence-based conclusion can be drawn from the limited, low quality evidence.

### Key Question 3 b Do patients treated with or decompression therapy for chronic low back pain due to herniated disc or degenerative disc disease utilize more, less, or the same number of adjunctive therapies (e.g., medications, bracing) than patients treated with other therapies?

The included studies did not provide data that would allow us to address this sub-question.

### Key Question 3 c Do patients treated with decompression therapy for chronic low back pain due to a herniated disc or degenerative disc disease return to work more quickly than patients treated with other therapies?

The included studies did not provide data that would allow us to address this sub-question. The study by Sherry et al. incorporated return to work into their definition of “remission,” but did not report return to work separately.(3)

### Key Question 3 d What is the duration of pain relief achieved, if any?

Sherry et al. (low quality study) reported that of 13 patients who had been “successfully treated” (defined as >50% improvement in pain and any improvement in disability ratings), two were lost to follow up, 1 had “suffered a significant other injury,” and of the 10 still available at 6 months, 7 still met criteria for a successful outcome.(3)

### Key Question 3 e If the therapy is effective, what are the patient characteristics/indications of those for whom it appears to work? Is the therapy effective for the Medicare population (over 65 years of age)?

As noted in Table 8, patients in the included studies were younger than the typical Medicare population. The limited quality and quantity of the evidence for efficacy of decompression therapy precludes the formulation of evidence-based conclusions regarding the efficacy of decompression therapy as a therapy for chronic low back pain for the Medicare population over the age of 65.

### Key Question 3 f If it works, which, if any, particular decompression protocol provides the most pain relief?

The two included studies did not compare different decompression protocols.

#### Subsection Summary

Because of a paucity of data from high quality studies, we do not draw evidence-based conclusions pertaining to the efficacy or effectiveness decompression therapy as a treatment option for the treatment of chronic low back pain due to herniated disc or degenerative disc disease at this time.

## Key Question #4 What complications, harms, and adverse events associated with decompression therapy have been reported?

All ten publications were examined for adverse events associated with decompression therapy. One case report of an adverse event was identified, Deen et al.(2)

### Quality

The quality and generalizability of the information were not formally evaluated because we included uncontrolled trials in the evidence base for this question. Uncontrolled studies cannot be used to determine causality or to estimate frequencies of adverse events; they can only be used to generate a list of adverse events possibly attributable to the device.

### Findings

Adverse events reported in the included articles are presented in Table 9. The technology assessment performed for the Australian government included unpublished information on adverse events submitted by the manufacturer of the VAX-D system.

Table 9 Adverse Events and Harms Associated with Decompression Therapy

Study | Year | N = | Adverse events and harms reported
Deen et al.(2) | 2003 | 1 | Case report of a patient who developed sudden, severe exacerbation of pain during a VAX-D treatment session. Follow-up MRI found a marked enlargement of the disc protrusion, and urgent microdiscectomy was performed. The patient recovered fully and was pain-free with no motor deficit
Gose et al.(5) | 1998 | 778 | One percent of patients reported increased pain
MSAC(4) | 2001 | NR | - “Anecdotal evidence from the applicant states that 10 per cent of patients are not able to tolerate the positioning of the table or the distractive pressures and discontinue therapy.”; - Complications that have been reported:; – Sharp burning, radiating pain during treatment; – Stress to the shoulder muscles and rotator cuffs; – Overstretching of the soft tissues of the back
Naguszewski et al.(9) | 2001 | 7 | No harms or adverse events mentioned in the 7 case descriptions.
Ramos(1) | 2004 | 142 | Presence or absence of harms or adverse events not reported.
Ramos and Martin(8) | 1994 | 5 | Presence or absence of harms or adverse events not reported.
Shealy et al.(10) | 2005 | 35 | Presence or absence of harms or adverse events not reported.
Shealy and Borgmeyer(6) | 1997 | 25 | Presence or absence of harms or adverse events not reported. (DRS system)
Sherry et al.(3) | 2001 | 22 | Presence or absence of harms or adverse events not reported.
Tilaro and Miskovich(7) | 1999 | 17 | Presence or absence of harms or adverse events not reported.

Adverse events have been reported to occur in association with vertebral axial decompression therapy (one case report of an enlargement of an existing disc protrusion and reports of treatment-related pain). According to the MSAC report presented to the Australian government in 2001,(4) information supplied by the manufacturer indicated that approximately 10% of individuals who undergo vertebral axial decompression therapy are unable to tolerate “the positioning of the table or the distractive pressures” and discontinue treatment. However, none of the published studies utilized in our report, including the large case series of Gose et al.(5) (which enrolled 778 patients) reported that any patients were unable to tolerate treatment, although one percent of the patients reported an increase in pain. Of note, this case series was limited to patients who had received at least 10 treatments, suggesting that those who did not tolerate the therapy were screened out.

### Key Question 4 a Would the characteristics of the Medicare population (osteoporosis, etc.) increase the likelihood of adverse events compared to the trial populations?

#### Findings

As noted in Table 12, patients in the included studies were younger than the typical Medicare population. Two studies included patients over the age of 65, but neither commented on the presence or absence of adverse effects.(1,10) Both studies excluded patients with “severe osteoporosis.” Currently, there is no evidence to establish whether characteristics of the Medicare population (such as presence of undiagnosed osteoporosis) would increase the likelihood of adverse events when compared to the trial populations, although it should be noted that the literature produced by manufacturers and distributors of decompression therapies lists osteoporosis as a contraindication for this therapy.

#### Subsection Summary

Inconsistencies in the data and the limited amount of published data preclude evidence-based conclusions pertaining to the type and frequency of adverse events. However, there has been one case report of an enlargement of an existing disc protrusion and other reports of treatment-related pain in the published literature.

## Conclusions

Patient inclusion criteria in studies of decompression therapy were chronic low back pain, with or without radicular symptoms, due to degenerative or herniated disc disease or facet arthritis. Product literature and the exclusion criteria in the examined studies suggest that therapy should be avoided in patients with osteoporosis, tumor, infection, spinal instability, and surgical implants. The health outcome measures reported in studies of decompression therapy (improvements in pain and radicular symptoms, improvements in function), are also reported in literature on other non-surgical treatments for low back pain. However, a number of additional outcomes (absenteeism, return to work, overall health, analgesic consumption, low back pain-related disability rates, and quality of life) have been reported for other non-surgical treatments.

Currently available evidence is presently too limited in quality and quantity to allow for the formulation of evidence-based conclusions regarding the efficacy of decompression therapy as a therapy for chronic back pain when compared with other non-surgical treatment options. Of the studies examined for assessment of efficacy, neither included patients over 65 years of age. Adverse event reporting for decompression therapy is infrequent. There was one case report of an enlargement of an existing disc protrusion, and other studies reported worsening of pain in some patients.