# Bibliography

1 Ramos G. Efficacy of vertebral axial decompression on chronic low back pain: study of dosage regimen. Neurol Res. Apr. 2004;26(3):320-4. [pmid: 15142327].
2 Deen HG Jr, Rizzo TD, Fenton DS. Sudden progression of lumbar disk protrusion during vertebral axial decompression traction therapy. Mayo Clin Proc. Dec. 2003;78(12):1554-6. [pmid: 14661685].
3 Sherry E, Kitchener P, Smart R. A prospective randomized controlled study of VAX-D and TENS for the treatment of chronic low back pain. Neurol Res. Oct. 2001;23(7):780-4. Also available: http://www.vaxd.net. [pmid: 11680522].
4 Medical Services Advisory Committee (MSAC). Vertebral axial decompression therapy for chronic low back pain: assessment report. Canberra ACT. Medical Services Advisory Committee. 2001. Jun. 29. p. (MSAC application; no. 1012). Also available: www.msac.gov.au/pdfs/msac1012.pdf.
5 Gose EE, Naguszewski WK, Naguszewski RK. Vertebral axial decompression therapy for pain associated with herniated or degenerated discs or facet syndrome: an outcome study. Neurol Res. Apr. 1998;20(3):186-90. Also available: http://www.vaxd.net/research.htm. [pmid: 9583577].
6 Shealy CN, Borgmeyer V. Decompression, reduction, and stabilization of the lumbar spine: a cost-effective treatment for lumbosacral pain. Am J Pain Manag. 1997;7:63-5.
7 Tilaro F, Miskovich D. The effects of vertebral axial decompression on sensory nerve dysfunction in patients with low back pain and radiculopathy. Can J Clin Med. 1999;6(1):2-7.
8 Ramos G, Martin W. Effects of vertebral axial decompression on intradiscal pressure. J Neurosurg. Sep. 1994;81(3):350-3. [pmid: 8057141].
9 Naguszewski WK, Naguszewski RK, Gose EE. Dermatomal somatosensory evoked potential demonstration of nerve root decompression after VAX-D therapy. Neurol Res. Oct. 2001;23(7):706-14. Also available: http://www.vaxd.net. [pmid: 11680509].
10 Shealy CN, Koladia N, Wesemann MM. Long-term effect analysis of IDD therapy in low back pain: a retrospective clinical pilot study. Am J Pain Manag. Jul. 2005;15(3):93-7.
11 van Tulder MW, Furlan AD, Gagnier JJ. Complementary and alternative therapies for low back pain. Baillieres Best Pract Res Clin Rheumatol. Aug. 2005;19(4):639-54.
12 Grabois M. Management of chronic low back pain. Am J Phys Med Rehabil. Mar. 2005;84(3 Suppl):S29-41. [pmid: 15722781].
13 Eurodisc; intervertebral disc degeneration: interplay of age, environmental and genetic factors. [internet]. Oxford (UK). University Laboratory of Physiology. Sep. accessed 2005 Oct 24. 2005:5. Available: http://www.physiol.ox.ac.uk/EURODISC/Progress.html.
14 Luo X, Pietrobon R, Sun SX, Liu GG, Hey L. Estimates and patterns of direct health care expenditures among individuals with back pain in the United States. Spine. Jan. 1. 2004;29(1):79-86. [pmid: 14699281].
15 Jones GT, Macfarlane GJ. Epidemiology of low back pain in children and adolescents. Arch Dis Child. Mar. 2005;90(3):312-6. [pmid: 15723927].
16 Manek NJ, MacGregor AJ. Epidemiology of back disorders: prevalence, risk factors, and prognosis. Curr Opin Rheumatol. Mar. 2005;17(2):134-40. [pmid: 15711224].
17 Carragee EJ. Clinical practice. Persistent low back pain. N Engl J Med. May. 5. 2005;352(18):1891-8. [pmid: 15872204].
18 Urban JP, Roberts S. Degeneration of the intervertebral disc. Arthritis Res Ther. 2003;5(3):120-30. [pmid: 12723977].
19 Hagen KB, Jamtvedt G, Hilde G, Winnem MF. The updated Cochrane review of bed rest for low back pain and sciatica. Spine. Mar. 1. 2005;30(5):542-6. [pmid: 15738787].
20 Mens JM. The use of medication in low back pain. Baillieres Best Pract Res Clin Rheumatol. Aug. 2005;19(4):609-21.
21 Hayden JA, van Tulder MW, Tomlinson G. Systematic review: strategies for using exercise therapy to improve outcomes in chronic low back pain. Ann Intern Med. May. 3. 2005;142(9):776-85. [pmid: 15867410].
22 Manheimer E, White A, Berman B, Forys K, Ernst E. Meta-analysis: acupuncture for low back pain. Ann Intern Med. Apr. 19. 2005;142(8):651-63. [pmid: 15838072].
23 Institute for Clinical Systems Improvement (ICSI). Adult low back pain. Bloomington (MN). Institute for Clinical Systems Improvement (ICSI). 2006. Sep. 65 p. Available: http://www.icsi.org/low_back_pain/adult_low_back_pain__8.html.
24 Patel AT, Ogle AA. Diagnosis and management of acute low back pain. Am Fam Physician. Mar. 15. 2000;61(6):1779-86. 1789. 90. [pmid: 10750882].
25 Submission and response to ECRI’s report ‘Vertebral axial decompression for the treatment of lumbosacral pain’. Oldsmar (FL). VAX-D Medical Technologies LLC. 2006. Oct. 4. various p.
26 Institute for Clinical Systems Improvement (ICSI). Adult low back pain. Bloomington (MN). Institute for Clinical Systems Improvement (ICSI). 2005. Sep. 64 p.
27 Medicare coverage database: VAX-D and MEDX - not proven effective (A26924). [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services. 2001. Feb. 1. accessed 2005 Nov 21. [various p]. Available: http://www.cms.hhs.gov/mcd.
28 Aetna. Coverage policy bulletin 0180: vertebral axial decompression therapy. [internet]. Hartford (CT). Aetna, Inc. Apr. 11. accessed 2006 Jun 29. 2006:5. Available: http://www.aetna.com/cpb/data/CPBA0180.html.
29 Blue Cross Blue Shield of Montana. From the medical director: benefits. Capsule News. 2001;(4th quarter):10.
30 Health Plan of Nevada. Denied medical technology: vertebral axial decompression (VAX-D) for low back pain. Las Vegas (NV). Health Plan of Nevada, Inc. 2003. Apr. 1 p.
31 Medica. Vertebral axial decompression (Vax-D) therapeutic table system. [internet]. Minnetonka (MN). Medica. Oct. 1. accessed 2005 Dec 13. 2002:2. Available: http://www.medica.com.
32 Regence Group. Vertebral axial decompression. Policy no. 45. [internet]. Portland (OR). Regence Group. 2005. Sep. 6. accessed 2005 Nov 22. [various p]. Available: http://www.regence.com.
33 Ohio Bureau of Workers’ Compensation. Billing and reimbursement manual. Columbus (OH). Ohio Bureau of Workers’ Compensation. Sep. Services. 2005;Chapter 3:3-1-3-86. Also available: http://www.ohiobwc.com/provider/services/brmdefault.asp#.
34 CareFirst. Medical policy updates: vertebral axial decompression. BlueLink (online). Nov–Dec. 2004;6(6):10.
35 Chalmers I, Adams M, Dickersin K, Hetherington J, Tarnow-Mordi W, Meinert C, Tonascia S, Chalmers TC. A cohort study of summary reports of controlled trials. JAMA. Mar. 9. 1990;263(10):1401-5. [pmid: 2304219].
36 Neinstein LS. A review of Society for Adolescent Medicine abstracts and Journal of Adolescent Health Care articles. J Adolesc Health Care. Mar. 1987;8(2):198-203. [pmid: 3818406].
37 De Bellefeuille C, Morrison CA, Tannock IF. The fate of abstracts submitted to a cancer meeting: factors which influence presentation and subsequent publication. Ann Oncol. Mar. 1992;3(3):187-91. [pmid: 1586615].
38 Scherer RW, Langenberg P. Full publication of results initially presented in abstracts. Cochrane Library. [Cochrane methodology review]. Oxford. Update Software. 2001;(2). accessed 2001 Apr 23. 35 p. Available: http://www.cochranelibrary.com.
39 Marx WF, Cloft HJ, Do HM, Kallmes DF. The fate of neuroradiologic abstracts presented at national meetings in 1993: rate of subsequent publication in peer-reviewed, indexed journals. Am J Neuroradiol. Jun–Jul. 1999;20(6):1173-7. [pmid: 10445467].
40 Yentis SM, Campbell FA, Lerman J. Publication of abstracts presented at anaesthesia meetings. Can J Anaesth. Jul. 1993;40(7):632-4. [pmid: 8403137].
41 Baker SG, Kramer BS. The transitive fallacy for randomized trials: If A bests B and B bests C in separate trials, is A better than C?. BMC Med Res Methodol. 2002;2:13. [pmid: 12429069].
42 Bucher HC, Guyatt GH, Griffith LE, Walter SD. The results of direct and indirect treatment comparisons in meta-analysis of randomized controlled trials. J Clin Epidemiol. Jun. 1997;50(6):683-91. [pmid: 9250266].
43 Treadwell JT, Tregear SJ, Reston JT, Turkelson CM. A system for rating the stability and strength of medical evidence. BMC Med Res Methodol. 2006;6:52. Also available: http://www.biomedcentral.com/1471-2288/6/52. [pmid: 17052350].
44 Assendelft WJ, Morton SC, Yu EI, Suttorp MJ, Shekelle PG. Spinal manipulative therapy for low back pain. A meta-analysis of effectiveness relative to other therapies. Ann Intern Med. Jun. 3. 2003;138(11):871-81. [pmid: 12779297].
45 Clarke JA, van Tulder MW, Blomberg SE, de Vet HC, van der Heijden GJ, Bronfort G. Traction for low-back pain with or without sciatica. The Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2005;(4). Oct. 19. [updated 2005 Aug 3]. accessed 2005 Oct 24. [Art. No. CD003010.pub3]. Available:. [doi: 10.1002/14651858.CD00310.pub3].
46 Bronfort G, Haas M, Evans RL, Bouter LM. Efficacy of spinal manipulation and mobilization for low back pain and neck pain: a systematic review and best evidence synthesis. Spine J. May–Jun. 2004;4(3):335-56. [pmid: 15125860].
47 Special report: the DRS system. [internet]. Baltimore (MD). CERT Health Sciences LLC. Oct. 1. accessed 2007 Feb 5. 1999:5. Available: http://www.certhealthsciences.com/research3.html.
48 Armitage P, Berry G. Statistical methods in medical research. 3rd ed. Oxford, England. Blackwell Scientific. 1994. 620 p.