# Background

In this section, we provide background information on lumbosacral pain (low back pain) and decompression therapy. The purpose of this section is to provide context for the research syntheses presented later in this report. The information presented in this section may be based upon opinion and we have not critically assessed its accuracy. This section is therefore not, in the strictest sense of the term, evidence-based. Consequently, no statement in this Background section should be interpreted as an endorsement or a criticism by ECRI.

## Lumbosacral Pain (Low back pain)

Low back pain is defined as pain, muscle tension, and/or stiffness localized below the costal margin and above the inferior gluteal folds, with or without leg pain.(11) It can be ‘specific’ (related to an organic disease such as osteoporosis or infection) or ‘non-specific’ (having no identifiable causes). Nociceptive, neuropathic, or psychological processes (or any combination of these processes) may cause low back pain. Nociceptive pain results from stretching of connective tissues or inflammation of innervated structures. Such pain is usually described as aching, dull, or throbbing.(12) Neuropathic pain is typically described as burning, shooting, or electrical in nature.(12) Both types of pain can result from any of a number of mechanical processes involving the spine and surrounding muscles, ligaments, joints, nerves, periosteum, blood vessels, and intervertebral discs.

Excessive mechanical loading and associated tissue damage have long been regarded as the main causes of low back pain, but recent research reveals that these environmental effects make only a modest contribution to vertebral pathology.(13) Herniated discs (compression of a spinal nerve by protrusion of the nucleus pulposus through the annulus fibrosus into the extradural space) can directly cause neuropathic pain (e.g., sciatica) and also cause mechanical injury leading to nociceptive pain due to compression or stretching of nerve roots.(12) Disc degeneration has been documented in asymptomatic groups age 11–16 years, with 20% of people in their teens demonstrating mild disc degeneration. By age 50, some 10% of discs show degenerative pathology, and by age 70, 60% of vertebral discs are severely degenerated. Disc degeneration alone is associated with sciatica, disc herniation and prolapse, alteration of disc height and concomitant adverse effects on other special structures of the spine such as muscles and ligaments, and, potentially, spinal stenosis.

### Extent of Problem

Low back pain is a major cause of disability and contributes substantially to economic and public health care burdens worldwide. In the United States, total health care expenditures to treat low back pain are estimated at $14 to $26 billion per year.(12,14) It has been estimated that low back pain will affect approximately 80% of the population at some point during the life span.(15) The prevalence of low back pain increases with age, peaking in the sixth decade. Women are affected more often than men.(15) In the United States, the 12-month prevalence of low back pain lasting ≥1 month has been reported to be 17.8% (males and females).(14)

### Risk Factors

A wide variety of risk factors, including gender, age, education level, smoking, occupation, high birth weight (males only), depression, and social support/work relations are thought to be associated with the occurrence and the severity of low back pain.(16) Obesity, health-care provider attitudes, unemployment, depression, fear-avoidance behavior, and unavailability of light duty work are associated with the development of chronic low back pain.(16,17) The single best predictor of future low back pain is a previous history of low back pain.(15)

There are a wide variety of anatomic, biomechanical, biochemical, and genetic risk factors associated with the development of common non-specific acute and chronic low back pain. Biomechanical risk factors associated with the development of disc degeneration include repetitive trauma, vibration, or injury. Biomechanical risk factors related to disc degeneration include radiographic disc space narrowing of lumbar vertebra, facet joint arthritis, anterior and posterior synovial cysts, lumbosacral transitional vertebra, Schmorl nodes, annular disruption, composition of herniated disc material, calcification of ligamentum flavum, and radiographic spondylolysis/spinal instability.

In a classic monozygotic twin study investigation of the potential for genetic influences on disc degeneration, the EURODISC research group in Finland demonstrated a dominant genetic component in lumbar disc degeneration with heritability estimates up to 74%. Inherited polymorphisms in the genes COL9A2 and COL9A3 (which encode proteins that are associated with Type IX collagen) have been found to increase the risk of developing low back pain, as have polymorphisms in the gene encoding for interleukin-1 (which may contribute to disc degeneration through the induction of proteoglycan-destroying enzymes ).(16)

Chronic disabling low back pain may occur more frequently in patients who have a high level of “fear avoidance” (an exaggerated fear of pain leading to avoidance of beneficial activities), psychological distress, or job dissatisfaction.(17,18)

### Diagnosis

Diagnosis of non-specific low back pain is complicated by the fact that a majority of imaging studies of individuals with low back pain reveal non-specific findings and no serious pathology. The probability that a particular case of low back pain has a specific identifiable cause is less than 1%.(16) Images of patients without low back pain commonly show the same pathological changes seen in individuals with low back pain, such as herniated disc, lumbar disc degeneration, signal changes in vertebral endplates, and annular fissures.(17) Medical evaluation of individuals presenting with low back pain primarily consists of a process of elimination—serious pathologies that may cause low back pain such as infection, tumors, and fractures need to be ruled out.(12) Laboratory tests such as erythrocyte sedimentation rate can establish the presence of infection or malignancy as a possible cause of the pain. Radiographic evaluation may be used for individuals with a medical history of cancer or corticosteroid use, or for those with a potential diagnosis of ankylosing spondylitis. Bone scintigraphy (bone scanning) is a potential diagnostic tool when clinical findings are suspicious for osteomyelitis, bony neoplasm or occult fracture.

Over 90% of patients recover spontaneously from episodes of low back pain within three months of onset.(12) Patients who remain active generally recover more quickly than patients who rest.(19) Physicians often prescribe pain relief medications and muscle relaxants to relieve symptoms during the healing period.(20)

### Aims of Treatment

For patients with chronic low back pain (defined as pain persisting over three months), the complete eradication of pain is rarely achieved. The goals of treatment for the chronic pain patient are moderation of pain, increased functional capacity, and decreased healthcare utilization.(12) Treatment usually requires an inter-disciplinary program of physical therapy, adjunctive therapies, psychosocial interventions, and pain medication.(12) Two adjunctive therapies (TENS and lumbar traction) used as comparators in studies of vertebral axial decompression and decompression therapy are discussed below. High-dose supervised exercise therapy has been reported to be beneficial for relief of chronic low back pain in a recent meta-analysis, as has acupuncture.(21,22) The Institute for Clinical Systems Improvement Health Care Guideline (Sept 2006) has provided a useful algorithm for the assessment and management of adult low back pain.(23)

## Decompression Therapy

Several different decompression therapy systems are available, including VAX-D, DRS, NuChoice Medical Healthstar Elite Decompression Therapy, Accu-Spina, AxiomWorldWide DRX9000, Antalgic-Trak, and Cert Health Services SpineMED. Each system utilizes a different treatment protocol.

Some decompression therapy system manufacturers recommend accompanying therapies such as pain medications, TENS treatment, exercise programs, relaxation programs, cold and/or heat applied to the back muscles, and/or physical therapy. The VAX-D system does not incorporate additional therapies in its treatment protocol, and in fact, the protocol advises against participation in exercise or physical therapy.

As VAX-D serves as the predicate device for the 510(k) FDA approved devices listed at the beginning of this section, an explanation of this technology appears below to provide more information on the basic principles of decompression of the spine.

### Vertebral Axial Decompression (VAX-D)

Vertebral axial decompression therapy is the proprietary acronym for the VAX-D system, which utilizes a specialized table and computer system to apply directed distractive tension to the vertebral column via a computerized logarithmic ramp-up and release protocol designed to bypass the body’s protective proprioceptor response. Proponents of the procedure contend that vertebral axial decompression therapy works by decreasing intra-discal pressure. This is believed to allow disc repositioning and triggers herniation shrinkage. Possible consequences of these physical changes may be the relief of nerve root compression, pain relief, and correcting of neurological deficits.

Vertebral axial decompression therapy is customized to the individual’s physical specifications (weight and height) and pathologies indicated through diagnostic testing such as MRI, CT scanning, provocative discography, bone scintigraphy, needle electromyography and nerve conduction studies.(17,24) Treatment is carried out by a vertebral axial decompression technician under medical supervision.

The VAX-D system employs a prone position, which requires the patient to lie on the treatment table face down. Other technologies coded as ITH powered traction equipment by the FDA use either a supine position or a sitting posture. In the prone posture system for VAX-D, the patient stands and is fitted with a pelvic harness. The patient then lies prone on the distraction table with the lower portion of the belt placed at the level of the table separation point.

According to the manufacturer, adjustable handgrips are positioned so that the patient’s elbows are straight, and the pelvic harness is repositioned, tightened, and attached to a movable pretension housing. Treatment begins with the application of approximately 50 lbs. of tension as the threshold necessary to develop negative intradiscal pressure. Tension is then applied in a logarithmic curve (in a reverse of the Weber-Fechner law to avoid proprioceptor response), with the application of force slowing down logarithmically as the tension increases. The tension is subsequently reduced to a secondary ‘baseline’ tension according to a reverse logarithmic time frame. The rest phase is the third phase of treatment whereby tension is maintained by a separate movable device/component. This cycle is repeated a programmed number of times to effect a therapy session.(25)

### Indications

Individuals with chronic low back pain that is resistant to conservative treatment.(3)

### Contraindications

Use of decompression therapy is contraindicated for patients with infection, neoplasm, osteoporosis, bilateral pars defect or unstable Grade 2 spondylolisthesis, fractures, surgical hardware in the spine, cauda equina syndrome, or who are in the latter stages of pregnancy. Decompression therapy is not meant to be used for the treatment of soft tissue injuries, sprains, strains, or progressive inflammatory conditions.(3)

### Care Setting

Decompression therapy is performed on an outpatient basis at a variety of locations, including chiropractic offices and low back pain treatment facilities.

## Competing/Complementary Technologies

Few therapies are available for the treatment of patients with chronic low back pain that is unresponsive to conservative therapy. Available treatment options include surgery or continued conservative management. (Table 1).(4,26)

Table 1 Available Treatment Options for Chronic Low Back Pain Unresponsive to Conservative Therapy

Treatment Option | Available Treatment Options Defined
Physical therapy and exercise | Application of heat, ice, ultrasound, transcutaneous electrical stimulation (TENS), exercise, and muscle release techniques
Prescription medications | NSAIDs, muscle relaxants, antidepressants, narcotics (opioids), anesthetic injections, cortisone injections, self-administered pain medications delivered via a catheter/programmed pump system to the spine.
Laminectomy and laminotomy | Surgical removal of part of the vertebra
Fusion | Joining of vertebrae to eliminate painful movement
Intradiscal electrothermal therapy (IDET) | The use of a heated needle, applied to the disc wall, to thicken and seal the disc and reduce disc bulge and related nerve irritation.

### TENS Therapy

TENS is a form of electroanalgesia used to relieve low back pain, myofascial and arthritic pain, neurogenic pain, visceral pain, and postsurgical pain. The electrical stimulation produced by the TENS device is thought to reduce pain through nociceptive inhibition at the presynaptic level in the dorsal horn of the spinal cord. Patients adjust the frequency and the intensity of electrical stimulation until they find the best settings for individual pain control.

### Lumbar Traction Therapy

Lumbar traction involves stretching the spine by any of a number of mechanisms. Stretching may relieve pressure in the intervertebral discs, enabling disc protrusions to recede and vertebrae to realign. Stretching may also relax spinal muscles. Although traction is often used to treat back pain, its efficacy has not been documented in controlled trials.

## Clinical Practice Guidelines

Our searches did not identify any clinical practice guidelines that specifically addressed the role of VAX-D or decompression therapy in the management of individuals with lumbosacral pain.

## Previous Systematic Reviews of Decompression Therapy

The Australian Medical Services Advisory Committee (MSAC) published a technology assessment on VAX-D therapy for low back pain in 2001.(4) The authors of this technology assessment concluded that there was no evidence to support the contention that VAX-D therapy reduces the need for surgical decompression of the spine in any patient group, including patients with non-specific low back pain. The authors noted that it does appear that VAX-D therapy may provide some short-term symptomatic relief from nerve root compression; however, there was no evidence that VAX-D therapy provided long-term relief or resolved nerve root compression.

## Ongoing Clinical Trials

ClinicalTrials.gov, which provides regularly updated information about federally and privately supported clinical research in human volunteers, listed one ongoing clinical trial examining the efficacy of decompression therapy in the treatment of low back pain. The official title of the study is Comparison of Internal Disc Decompression (IDD®) vs. a Standardized Non-Surgical Treatment Program for Chronic Low Back Pain Secondary to Mild to Moderate Degenerative Disc Disease. The study, which uses the Accu-Spina device, was scheduled for completion in December 2006.

## Regulatory Issues

### Manufacturers and U.S. Food and Drug Administration (FDA) Status

VAX-D (vertebral axial decompression) was designated an FDA-mandated Class II medical device in 1996 under the product code ITH, meaning it is classified as “equipment, powered traction”. This classification means that each new device requires FDA 510k clearance before it can be marketed in the U.S. Nine ITH product coded decompression devices have been approved or cleared for marketing by the FDA since the approval of the first device, the VAX-D Therapeutic Table, which was manufactured by Vat-Tech, Inc. of Palm Harbor, FL. The nine spinal decompression devices (VAX-D and spinal decompression) that have obtained FDA 510k clearance are listed in Table 2.

Table 2 Decompression Devices

Device Name | Manufacturer | FDA 510k Clearance Date
Accu-Spina System | North American Medical Corporation 1649 Sands P1 SE, Suite A Marietta GA 30067 | 8/25/00
Spinemed S200b/S200c | Cert Health Sciences 7036 Golden Ring Road Baltimore, MD 21237 | 4/27/05
Bass Antalgic-Trak | Spinetronics LLC 9737 NW 65 Pl. Parkland, FL 33076 | 3/21/05
Healthstar Elite | NuChoice Medical 3162 Thoroughbred Loop W Lakeland, FL 33811 | 12/22/04
SpineRx-LDM | SpineRx Technology 6100 Brittmoore Road Bldg. S Houston, TX 77041 | 10/31/03
Lordex Power Traction | Lordex Inc. 15915 Katy Freeway Suite 645 Houston, TX 77094 | 7/17/03
DRX9000 | Axiom WorldWide, Inc. 9423 Corporate Lake Drive Tampa, FL 33634 | 1/23/03
DRS System | Professional Distribution Systems, Inc. 1160 S Rogers Bldg A Boca Raton, FL 33487 | 6/24/98
VAX-D Therapeutic Table | VAX-D Medical Technologies LLC 310 Mears Blvd. Oldsmar, FL 34677 | 7/02/96

## Training and Credentialing of Personnel to Use Decompression Therapy Machinery

VAX-D Medical Technologies LLC of Oldsmar, FL, offers a training and credentialing program for physicians and staff involved in the use of VAX-D (vertebral axial decompression therapy systems) (see: http://www.vaxd.com/Pages/EquipmentPurchase/VAXDEquipment.html). North American Medical Corporation (the manufacturer of the AccuSpina system, which utilizes IDD® or Intervertebral Differential Dynamics Therapy system) refers on its Web site (http://www.iddtherapy.com/ENGLISH/find_certified.html) to ‘certified IDD® facilities’ and ‘certified clinicians;’ however, the certification process is not explained on the Web site. The Web site does note that “usually a certified factory-trained Physical Therapist” provides a six- to eight-hour training session. Training and credentialing information for other decompression systems listed in this report was not available on company Web sites.

## CMS Coverage Policy

Medicare Coverage Issues Manual transmittal 161, effective date 1 April 2003(27) states the following: “Vertebral axial decompression is performed for symptomatic relief of pain associated with lumbar disc problems. The treatment combines pelvic and/or cervical traction connected to a special table that permits the traction application. There is insufficient scientific data to support the benefits of this technique. Therefore, VAX-D is not covered by Medicare.”

## Third Party Payer Coverage

We searched the following Web sites for reimbursement information:

- Aetna US Healthcare
  (http://www.aetna.com/cpb/data/CPBA0180.html)
- Blue Cross/Blue Shield of Massachusetts
  (http://bcbsma.com)
- Blue Cross of California
  (http://medpolicy.bluecrossca.com/policies/SURG/spinal_therapy.html)
- Blue Cross/Blue Shield of Montana
  (http://www.bcbsmt.com/providers/Assets-Providers/Downloads-Providers/Source-Provider_Publications/pub_prov_capnews4q01.pdf)
- CareFirst of Maryland
  (http://www.carefirst.com)
- CMS Coverage Issues Manuals
  (http://cms.hhs.gov/manuals/06_cim/ci00.asp)
- Cigna
  (http://www.cigna.com/health/provider/medical/procedural/coverage_positions/medical/mm_0002_coveragepositioncriteria_vax_d.pdf)
- Health Care Plan of Nevada (subsidiary of Sierra Health Services, Inc.)
  (http://www.healthplanofnevada.com/documents/provider%20files/New%20Medical%20Technology/New%20Medical%20Technology%20-%20Denied%2006092003.pdf)
- Humana
  (http://apps.humana.com/tad/tad_new/returnContent.asp?mime=application/pdf&id=4846&issue=741)
- Medica
  (http://provider.medica.com/router/default.pdf?doc=/C1/CoveragePolicies/Document%20Library/VaxD_CP.pdf)
- OhioBWC
  (www.ohiobwc.com/downloads/blankpdf/BRM3.pdf)
- Regence Blue Shield
  (http://www.regence.com/trgmedpol/medicine/med45.html)
- Wellmark Blue Cross/Blue Shield
  (http://www.wellmark.com)

We also used the Google and Vivisimo Internet search engines to locate reimbursement information, using search terms: (reimburs* OR coverage OR “medical policy” OR “Medicaid”).

Aetna, BlueCross/BlueShield of Massachusetts, BlueCross/BlueShield of Montana, Blue Cross of California, CIGNA Healthcare, Health Care Plan of Nevada, Humana, Medica and Regence did not cover vertebral axial decompression (VAX-D) therapy.(28–32) CareFirst of Maryland, First Health Services Corporation, Alaska,(25), South Dakota Department of Labor(25), Arizona State Fund (Workers Compensation Insurance)(25), OhioBWC, and Wellmark Blue Cross/Blue Shield(33) cover VAX-D therapy.(34)