# Evidence Tables

Table 12 Summary of Included Studies (by Study Design)

Author/Year | Study Design/Purpose | Intervention | Demographics | Results
Medical Services Advisory Committee (MSAC) 2001(4) | Design: Technology Assessment of vertebral axial decompression therapy for chronic low back pain which included a systematic review of published and unpublished studies for efficacy and adverse events Purpose: To provide evidence assessment for health care financing decisions for Commonwealth of Australia | Treatment Intervention: VAX-D device (2 published and 2 unpublished studies) Comparators: Indirect comparisons to discectomy, laminectomy and conservative therapy (NSAIDs or physical therapy) | Not described; Conditions considered separately: Radiculopathy or radicular pain caused by herniated intervertebral disc, unresponsive to conservative therapy Radiculopathy or radicular pain caused by degenerated intervertebral disc, unresponsive to conservative therapy Chronic non-specific low back pain, unresponsive to conservative therapy | Insufficient evidence pertaining to the effectiveness of vertebral axial decompression (VAX-D) therapy precluded MSAC from recommending that public funding should be supported at the time for the VAX-D procedure.
Shealy and Borgmeyer 1997(6) | Design: Randomized controlled trial (RCT) Purpose: To evaluate the DRS system with outpatient protocols compared to traditional therapy Quality Score: 6.6 | Treatment Intervention: DRS System 30 minute treatment sessions 60 seconds on, 60 seconds off Up to 30 degrees of distraction forces 20 sessions total 30 minutes of ice and TENS applied after each session Control Intervention: Standard traction 30 minute treatment sessions 60 seconds on, 60 seconds off 20 sessions total 30 minutes of ice and TENS applied after each session Other intervention: All patients were given a TENS unit for continuous home use, and were instructed and supervised in a limbering/strengthening exercise program | Total Enrolled: 39 in total 17 control group 22 treatment group Mean age: Mean not reported range 31 to 63 Gender: 30.7% Female Ethnicity: Not reported Inclusion Criteria: Ruptured lumbar discs and/or chronic facet arthroses (23 had ruptured discs diagnosed by MRI) Exclusion Criteria: Not reported Average duration of pain before entering trial: All had symptoms of less than one year | Baseline VAS scores mean (range) Treatment: NR Control: NR Definition of successful treatment: Patient-rated scale: Excellent 90–100% improvement in pain Good 50–89% improvement in pain Poor <50% improvement in pain Treatment outcome: 40.9% (9/22) Excellent 40.9% (9/22) Good 18.2% (4/22) Poor For patients with disc protrusion only: 50% (7/14) Excellent 36% (5/14) Good 14% (2/14) Poor Control group outcome: 11.7% (2/17) Excellent 41.2% (7/17) Good 47.1% (8/17) Poor For patients with disc protrusion only: 0% (0/9) Excellent 55% (5/9) Good 45% (4/9) Poor 6 months follow-up Treatment: NR Control: NR
Sherry et al. 2001(3) | Design: RCT Purpose: To address the question of efficacy and appropriateness of vertebral axial decompression therapy Source of patients: Volunteers responding to newspaper advertisements Quality Score: 6.6 | Treatment Intervention: VAX-D machine, standard protocol Prone position 30 minute sessions 15 cycles per session Five times per week for 4 weeks, then once per week for 4 weeks Control Intervention: TENS Prone position 30 minute sessions Daily sessions for 20 days, then once a week for 4 weeks (not a normal TENS protocol, this is considered a sub-optimal treatment) Other Intervention: No physical therapy, steroid injection, or other treatments allowed during the trial. Non-narcotic pain relievers and anti-inflammatory medications could be taken if necessary | Total Enrolled: 44 22 per group Mean age: All: 42 (22–57) VAX-D: 41 (27–57) TENS: 43 (27–55) Gender: All: 47.7% VAX-D: 50.0% TENS: 45.5% Ethnicity: All: 90.9% white 9.1% Asian VAX-D: 90.9% white 9.1% Asian TENS: 90.9% white 9.1% Asian Inclusion Criteria: Chronic low back pain (>3 months duration) Associated leg pain Disc protrusion or herniation confirmed on CT scan or MRI Age 18 to 65 years Minimum VAS score of 2.0 Live within 45 minutes of the clinic Able to give informed consent Exclusion Criteria: Osseous stenosis Unstable spine Spinal surgical implants Shoulder problems Spinal pain due to tumor, infection, or inflammatory disease Pregnancy Previous VAX-D therapy Average duration of pain before entering trial: All: 7.3 years (0.25 to 30) VAX-D: 8.4 years (0.25 to 30) TENS: 6.2 years (0.5 to 2.8) | Baseline VAS scores mean (range) Treatment: 5.99 (2.1 to 8.7), n = 19 Control: 5.44 (2.7 to 8.5), n = 21 Post-treatment VAS scores mean (range) Treatment: 1.85 (0.0 to 5.6), n = 19 Control: 5.97 (1.8 to 8.5). n = 21 Disability Rating (1 [most] to 4 [least disability] scale) mean (range): Baseline: Treatment 2.2 (1.5 to 3) Control 2.2 (1.8 to 3.0) Post-treatment: Treatment 2.9 (2.0 – 4.0) Control 2.2 (1.5 to 3.0) Definition of successful treatment: 50% reduction in pain Treatment outcome: 68.4% (13/19) Control group outcome: 0% (0/21) 6-month follow-up Treatment: Of 13 “successful” treatments, 2 were lost to followup, 1 had a “significant other injury,” and of the remaining 10, 7 (70%) still met the successful treatment criteria Control: NR
Ramos 2004(1) | Design: Controlled trial. Purpose: To evaluate the response to VAX-D therapy Source of patients: Cases referred to the center for neurosurgical evaluation after failure to respond to other treatments for low back pain Quality Score: 4.1 | Treatment Intervention: VAX-D device 30 minute sessions 15 cycles per session Five sessions per week for a total of 20 sessions Control Intervention: VAX-D device 30 minute sessions 15 cycles per session Five sessions per week for a total of 10 sessions Other Intervention: No exercises, stretching, or other physical therapy allowed. Pain relieving medication was allowed as necessary | Total Enrolled: 142 91 in control group 51 in treatment group Mean Age in years and range: Mean 39.5 (15–76) Percentage over 65 y/a not reported. Gender: 38.7% female Ethnicity: N/R Inclusion Criteria: Low back pain, non-progressive neurological deficits, no contraindications to VAX-D. All patients were imaged with MRI or CT to confirm presence of discogenic disorder Exclusion Criteria: Cauda equina syndrome, tumor, infection, severe osteoporosis, fracture, bilateral pars defect, spondylolisthesis Grade 2, presence of surgical hardware Average duration of pain before entering trial: 10 months | Baseline VAS scores mean (range) Treatment: NR Control: NR Definition of remission: 90% reduction in pain, back to work without restriction Treatment group outcome: 76.5% (39/51) Control group outcome: 42.9% (39/91) Partial Remission: Some persistent pain; able to carry out most ADL’s Treatment group outcome: 19.6% (10/51) Control group outcome: 24.1% (22/91)
Gose et al. (1998)(5) | Case series | Treatment Intervention: VAX-D machine | Total patients: 778 Inclusion Criteria: Patients must have undergone at least 10 sessions of VAX-D. Patients must have had a confirmed (through imaging studies) diagnosis of herniated disc, degenerative disc, or facet syndrome Exclusion criteria: Not reported Group 1: Extruded herniated disc(s) n = 34 Group 2: Multiple herniated discs without extrusion n = 195 Group 3: Single herniated disc, regardless of degenerative disease n = 382 Group 4: Degenerative disc disease n = 147 Group 5: Facet syndrome n = 19 | Baseline VAS scores (scale 0 – 5) means (no SD) Group 1: 4.16 Group 2: 4.13 Group 3: 4.16 Group 4: 3.93 Group 5: 4.00 Post-treatment VAS scores (scale 0 – 5) means (no SD) Group 1: 1.82 Group 2: 1.18 Group 3: 1.09 Group 4: 1.17 Group 5: 1.13 % VAS score Improvement Group 1: 53% Group 2: 72% Group 3: 71% Group 4: 70% Group 5: 72% Activity limitation (scale 0 – 3) means (no SD): All patients pre: 1.24 All patients post: 0.27
Shealy et al.(10) | Design: Case Series Purpose: To evaluate long-term benefits of Intervertebral Differential Dynamics (IDD) Therapy® | Treatment: Described as decompressive mobilization of the spine as in Shealy and Borgmeyer 1997(6) with an expanded physical therapy component; 25 – 30 minute sessions for decompression (for compressed discs) and/or mobilization (for facet syndrome) Utilized the Accu-Spina device | Total enrolled: 35 Male: 18 Female: 17 Age: mean 73.5 years, SD 6.9 Prior treatments: in 16 of 35 Acupuncture, back support, back surgery, chiropractic, epidural block, pain medication, conventional physical therapy, trigger point injections Inclusion Criteria: Low back pain with or without previous failed attempts with other treatments Exclusion Criteria: Severe osteoporosis, vertebral fractures, spondylolisthesis of grade 2 or higher, unstable post-surgical conditions, any kind of surgical hardware, spinal instability, inability to give legal consent | Reported for 24 patients at one year follow-up 2 patients unable to complete the treatment 9 patients could not be contacted at time of one-year follow up Mean pain score (0 – 10) on a numeric pain scale First session: 6.88 (SD: 2.47) (Unclear whether this represents score for all 35) Last session: 2.42 (SD: 2.18) One-year follow-up: 1.65 (SD: 2.47)
Naguszewski et al. (2001)(9) | Design: Case Series Purpose: To use dermatomal somatosensory evoked potentials (DSSEPs) to demonstrate lumbar root decompression following VAX-D therapy | Treatment: VAX-D therapy. Each patient underwent DSSEPs of the L5 and S1 immediately before and within two weeks of VAX-D therapy. | Total Enrolled: 7 28 nerve roots studied before and after VAX-D therapy Gender: Male: 57% (n = 4) Female: 43% (n = 3) Age Range: 23 to 56 years of age Inclusion criteria: Low back pain with referred pain in L5 and/or S1 distribution; disc bulging or herniation on imaging study Exclusion criteria: Not reported | Average pain reduction: 77% Improvement in radicular symptoms by 50%: 100% of patients Improvement in radicular symptoms by 100%: 43% of patients Improvement in DSSEP in ipsilateral or contralateral leg after VAX-D therapy: 100% of patients Deterioration of DSSEP in symptomatic leg in 2 (28.5%) patients despite clinically significant improvement in pain and radicular symptoms Seventeen nerve root responses improved, eight remained unchanged, and three deteriorated.
Ramos and Martin (1994)(8) | Design: Case Series Purpose: To examine the effect of vertebral axial decompression on pressure in the nucleus pulposus of lumbar discs Source of patients: Patients with work-related back injury referred for neurosurgical evaluation | Individuals with a cannula introduced into the nucleus pulposus of the L4–5 intervertebral disc underwent testing using a VAX-D machine. The purpose of this testing was to determine potential changes in intradiscal pressure associated VAX-D treatment. Digital readouts of intradiscal pressure were observed and recorded. | Total enrolled: 5 No information presented on the following: Gender Mean Age Ethnicity Inclusion Criteria: Patients with lumbar disc herniation confirmed by MRI and selected for percutaneous discectomy Exclusion Criteria: not reported | Tension associated with treatment was observed to decompress the nucleus pulposus to below -100 mm/Hg
Tilaro and Miskovich (1999)(7) | Case Series - Retrospective chart review Source of patients: Patients attending an outpatient VAX-D clinic. | Treatment Intervention: VAX-D machine (3–5 sessions per week, for an average of 23 total treatments) | N = 17 Number of involved nerves: 22 Gender: 13 males, 4 females Age: Average age 40.8 years old Average duration of symptoms: 17.2 months Inclusion criteria: Selected cases with both abnormal CPT (current perception threshold) results and sciatica, positive SLR and imaging study correlation with observed clinical syndrome Three patients had multilevel involvement. CPT(scores: 5 – 11 | CPT scores: 14/22 nerves: returned to normal function (64%) 6/22 nerves: improved (27%) 1/22 nerves: had no improvement (4.5%) 1/22 nerves: was worse (4.5%) 91% demonstrated improved neurological function measured by CPT Neurometer post VAX-D therapy (average grade pre-therapy 6.36; post-therapy 2.09) Overall improvement: 67% Complete recovery of neurological function: 64%
Deen et al. 2003(2) | Case Report | Vertebral axial decompression | Gender: Male Age: 46 years of age Pre-VAX-D Diagnosis: Three month history of right S1 radiculopathy | Patient with a large lumbar disc protrusion experienced sudden severe exacerbation of radicular pain during a VAX-D therapy session. Follow-up MRI showed marked enlargement of the disc protrusion. Repeated lumbar MRI revealed notable progression of disc protrusion and large free disc fragment in the spinal canal which had migrated caudally to the level of the S1 pedicle.

a Calculated by ECRI.

CPT = Current Perception Threshold

95% CI = 95% Confidence Interval

NR = Not Reported

SD = Standard Deviation

VAS = Visual Analog Pain Scale

Table 13 Comparison of Outcomes Assessed by Studies of Decompression Therapy and Other Non Surgical LBP Treatments

Technology | Author | Year | Pain scores (VAS) or pain improvement | Functional status | Physiological variables | Short term duration of effects | Long term duration of effects | Absenteeism | Global improvement | Return to work | Overall health | Analgesic consumption | Recovery time | Work loss | Nerve conduction | Gait Analysis | Overall quality of life | Overall improvement | Return to full work | Low back disability
Studies of decompression therapy
DRS (Decompression Reduction System) | Shealy and Borgmeyer(6) | 1997 | ✓
IDD (Intervertebral Differential Dynamics) Therapy® | Shealy et al.(10) | 2005 | ✓
Vertebral axial decompression | Ramos(1) | 2004 | ✓ | ✓
Vertebral axial decompression | Sherry et al.(3) | 2001 | ✓ | ✓
Vertebral axial decompression | Gose et al.(5) | 1998 | ✓ | ✓
Vertebral axial decompression | Tilaro and Miskovich(7) | 1999 | | | ✓
Vertebral axial decompression | Ramos and Martin(8) | 1994 | | | ✓
Vertebral axial decompression | Naguszewski et al.(9) | 2001 | ✓ | | ✓
Studies of other non-surgical LBP treatment options
SMT (systematic review) | Cochrane(44) | 2005 | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓ | | | ✓ | ✓
Traction (systematic review) | Cochrane(45) | 2005 | ✓ | ✓ | | | | | ✓ | ✓
CAM (systematic review) | Gagnier(11) | 2005 | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓ | ✓ | ✓
Acupuncture (meta-analysis) | Manheimer(22) | 2005 | ✓ | ✓ | | ✓ | ✓ | | | | | ✓ | | | | | | ✓ | ✓
Exercise Therapy (systematic review) | Hayden(21) | 2005 | ✓ | ✓
SMT (systematic review) | Bronfort(46) | 2004 | ✓ | ✓ | | ✓ | ✓ | | ✓ | | | ✓ | ✓ | ✓ | | | | | | ✓

CAM = Complimentary and Alternative Medicine

CG = Control Group

CPT = Current Perception Threshold

MOB = Spinal Mobilization

NR = Not Reported

SMT = Spinal Manipulation Therapy

TG = Treatment Group

Table 14 Study Design Details of Studies that Address Key Question 3 (Part I of II)

Study | Study purpose | Design | Treatment intervention | Control intervention | Other interventions
Ramos 2004(1) | To evaluate the response to VAX-D therapy | Controlled trial, control group treated first, then treatment group | VAX-D machine 30 minute sessions 15 cycles per session Five sessions per week for a total of 20 sessions | VAX-D machine 30 minute sessions 15 cycles per session Five sessions per week for a total of 10 sessions | No exercises, stretching, or other physical therapy allowed. Pain relieving medication was allowed as necessary.
Sherry et al. 2001(3) | To address the question of efficacy and appropriateness of vertebral axial decompression therapy | Prospective randomized controlled trial | VAX-D machine, standard protocol Prone position 30 minute sessions 15 cycles per session Five times per week for 4 weeks, then once per week for 4 weeks | TENS Prone position 30 minute sessions Daily sessions for 20 days, then once a week for 4 weeks (not a normal TENS protocol, this is considered a sub­ optimal treatment) | No physical therapy, steroid injection, or other treatments allowed during the trial. Non-narcotic pain relievers and anti­ inflammatory medications could be taken if necessary
Shealy and Borgmeyer 1997(6) | To evaluate the DRS system with outpatient protocols compared to traditional therapy | Prospective randomized controlled trial | DRS System-n 30 minute treatment sessions 60 seconds on, 60 seconds off Up to 30 degrees of distraction forces 20 sessions total 30 minutes of ice and TENS applied after each session | Standard traction 30 minute treatment sessions 60 seconds on, 60 seconds off 20 sessions total 30 minutes of ice and TENS applied after each session | All patients were given a TENS unit for continuous home use, and were instructed and supervised in a limbering/strengthening exercise program

Table 15 Study Design Details of Studies that Address Key Question 3 (Part II of II)

Study | Method of allocation to groups | Outcomes collected | Number of treatment centers | Patients blind to treatment? | Outcome evaluators blind to treatment? | Dropouts | Loss to follow up | ITT analysis? | Study funded by/conflicts of interest
Ramos 2004(1) | Patients enrolled first were allocated to the control group, patients enrolled later were allocated to the treatment group | Remission of pain (defined as at least 90% reduction in pain on 10 cm VAS), ability to carry out ADLs, return to work | 1 | No | No | NR | Average number of sessions was 9 in the control group, 18 in the treatment group | Yes | Author statement that he has no financial interest or affiliation with the company that manufactures the VAX-D equipment
Sherry et al. 2001(3) | Patients were randomized in sequential order (a pseudo-randomization method). Not reported if allocation was blinded. | Successful treatment (defined as a 50% reduction in pain on 10 cm VAS) Improvement in disability (patient­ nominated 4-point disability rating). Outcomes collected before treatment initiated and after treatment was completed, and six months later | 4 | No | NR | 2 patients withdrew, one from each group: TENS because “did not wish to continue”, VAX-D because “no longer needed treatment”. Two patients were randomized, but found to have VAS baseline score <2, so they were excluded (both were randomized to VAX-D) | VAX-D: mean 24.1 treatments per patient, range 18–36; TENS: mean 18.0 treatments per patient, range 10–24. Only reported data at 6-month follow up for “successful” cases. | No | Co-author is contracted to and holds shares in company that delivers VAX-D technology and services
Shealy and Borgmeyer 1997(6) | Randomly assigned, method used not reported | Patient assessment of pain relief on a categorical scale | 1 | Yes | NR | Not reported | NR | NR | Author (Shealy) developed the DRS device (http://www.certhealthsciences.com/research3.html); Co-author (Borgmeyer) is a research coordinator at The Shealy Institute, which utilizes DRS technology in its therapeutic programs.(47)

ITT = Intent-to-Treat

NR = Not Reported

Table 16 Quality Assessment of Studies Addressing Key Question 3

Reference | Randomized? | Stochastic randomization? | Other methods used to attempt comparability between groups? | Patients assigned to groups based on factors other than patient or physician preference? | Baseline patient characteristics comparable? | Baseline performance levels comparable? | Comparison of interest prospectively planned? | Treatment group and control group concurrently treated? | Outcome measure objective? | Same outcome measures in both groups? | Standardized instrument used to assess outcomes? | All of the study’s groups treated at the same center? | Subjects blinded? | Blinding of subjects tested? | Treating physicians blinded? | Assessors blinded? | Concealment of allocation? | Same treatment given to patients enrolled in experimental group? | Same treatment given to patients enrolled in control group? | Compliance ≥85% in both the study’s groups? | Total attrition rate in the study ≤15%? | ≤15% difference in attrition between groups? | Follow-up times in all of the study’s groups approximately equal? | Study free from potential financial conflict of interest? | Authors conclusions supported by data presented? | Quality score =
Ramos(1) | N | N | N | N | NR | NR | NR | N | N | Y | N | Y | N | N | N | N | N | Y | Y | NR | NR | NR | Y | Y | Y | 4.1
Shealy and Borgmeyer(6) | Y | NR | Y | Y | NR | NR | Y | Y | N | Y | N | Y | Y | NR | NR | N | NR | Y | Y | Y | Y | Y | Y | N | Y | 6.6
Sherry et al.(3) | Y | N | Y | Y | Y | Y | Y | Y | N | Y | Y | Y | N | N | N | N | NR | Y | Y | Y | Y | Y | Y | N | Y | 6.6

N = No

Y = Yes

NR = Not Reported

Table 17 Studies that Address Key Question 3: Pain Outcomes: VAS Scores

Study | Baseline VAS scores mean (range) | | Post-treatment^*^ VAS scores mean (range)
Study | Treatment | Control | Treatment | Control
Sherry et al. 2001(3) | 5.99 (2.1 to 8.7) n = 19 | 5.44 (2.7 to 8.5) n = 21 | 1.85 (0.0 to 5.6) n = 19 | 5.97 (1.8 to 8.5) n = 21

VAS = Visual Analog Scale

Table 18 Studies that Address Key Question 3: Number of Patients Successfully Treated

Study | Definition of success | Post-treatment | | 6-month follow up
Study | Definition of success | Treatment | Control | Treatment | Control
Sherry et al. 2001(3) | 50% reduction in pain | 68.4%^*^ (13/19) | 0% (0/21) | Of 13 “successful” treatments, 2 were lost to followup and 70% still met the successful treatment criteria | NR
Shealy and Borgmeyer 1997(6) | Patient-rated scale: Excellent 90–100% improvement in pain Good 50–89% improvement in pain Poor <50% improvement in pain | 40.9% (9/22) Excellent 40.9% (9/22) Good 18.2% (4/22) Poor For patients with disc protrusion only: 50% (7/14) Excellent 36% (5/14) Good 14% (2/14) Poor For patients with facet arthrosis: 25% (2/8) Excellent 50% (4/8) Good 25% (2/8) Poor | 11.7% (2/17) Excellent 41.2% (7/17) Good 47.1% (8/17) Poor For patients with disc protrusion only: 0% (0/9) Excellent 55% (5/9) Good 45% (4/9) Poor For patients with facet arthrosis: 25% (2/8) Excellent 25% (2/8) Good 50% (4/8) Poor | NR | NR

NR = Not Reported

* p < 0.001, Confidence Interval: 47.5% – 89.3% for difference in proportions