# Quality Assessment and Strength of Body of Evidence Rating (Key Question 3)

## Study Quality Evaluation Scale

The 25-item quality assessment instrument used to assess the quality of the three studies that addressed Key Question 3 is presented below:

Comparability of Groups at Baseline
1 Were patients randomly assigned to the study’s groups?
2 Did the study employ stochastic randomization?
3 Were any methods other than randomization used to make the patients in the study’s groups comparable?
4 Were patients assigned to groups based on factors other than patient or physician preference?
5 Were the characteristics of patients in the different study groups comparable at the time they were assigned to groups?
6 Did patients in the different study groups have similar levels of performance on all of the outcome variables at the time they were assigned to groups?
7 Was the comparison of interest prospectively planned?
8 Did ≥85% of the patients complete the study?
9 Was there a ≤15% difference in completion rates in the study’s groups?
10 Were all of the study’s groups concurrently treated?
11 Was compliance with treatment ≥85% in both of the study’s groups?
12 Was there concealment of allocation?

Blinding
13 Were subjects blinded to the treatment they received?
14 Did the authors perform any tests after completing the study to ensure that the integrity of the blinding of patients was maintained throughout the study?
15 Was the treating physician blinded to the groups to which the patients were assigned?
16 Were those who assessed the patient’s outcomes blinded to the group to which the patients were assigned?

Measurement/Instrument
17 Was the outcome measure of interest objective and was it objectively measured?
18 Were the same laboratory tests, clinical findings, psychological instruments, etc., used to measure the outcomes in all of the study’s groups?
19 Was the instrument used to measure the outcome standard?
20 Were the follow-up times in all of the study’s relevant groups approximately equal?

Treatment
21 Was the same treatment given to all patients enrolled in the experimental group?
22 Was the same treatment given to all patients enrolled in the control group?
23 Were all of the study’s groups treated at the same center?

Investigator Bias
24 Was the funding for this study derived from a source that does not have a financial interest in its results?
25 Were the author’s conclusions, as stated in the abstract or the article’s discussion section, supported by the data presented in the article’s results section?

## Strength of Body of Evidence Algorithm

In addressing Key Question 3, we used an algorithm developed by ECRI to determine the strength of the evidence supporting our conclusions. This algorithm formalizes the process of systematic review by breaking the process down into 12 discrete steps. At each step, rules that have been determined prior to the onset of the review, are applied that determine the next step in the systematic review process and ultimately the stability and strength-of-evidence ratings allocated to our findings. Because the application of the rules governing each step in the algorithm (henceforth called a decision point) guide the conduct of the systematic review process and how its findings are interpreted, much time and effort must be spent prior to the onset of data collection in ensuring that the rules and underlying assumptions for each decision point are reasonable. For the sake of transparency, all rules and assumptions made prior to the onset of this evidence report are included in the text that follows.

The algorithm is comprised of three distinct sections: a General section, a Quantitative section, and a Qualitative section. Only the General section is relevant to this report.

## General Section of Algorithm

Decision Points 1 through 4 fall within the General section. The purpose of this section is to determine whether the available evidence for a given key question is sufficient (in terms of quality and power) to potentially allow evidence-based conclusions to be drawn (Decision Points 1 and 2). Assuming that the available evidence is deemed sufficient to allow evidence-based conclusions to be drawn, the next step of the general section (Decision Point 3) is to determine the overall quality of the available evidence. Regardless of the quality of the available evidence, it may be the case that the available data precludes one from performing a quantitative analysis. The purpose of the final decision point in the general section of the algorithm (Decision Point 4) is to provide a mechanism by which decision rules about the appropriateness of performing quantitative analyses can be formally determined.

### Decision Point 1 Acceptable Quality?

Decision Point 1 provides a mechanism by which individual studies of very low quality are excluded from further consideration. Decision rules that define exactly what one considers to be a study of unacceptable quality are defined a priori. These decision rules depend on the mechanism that one is using to measure study quality. For example, if one is using a scale to measure study quality, one might determine that a quality score that falls below a certain threshold is unacceptable. Alternatively, if one is using a checklist, one might determine that certain study characteristics included among the checklist items must be met for the study to be considered acceptable (e.g., randomization, blinding, etc.).

For this evidence report, we determined whether a study was of acceptable quality based on group comparability scores obtained using the quality checklist instrument presented above. In order for a study to be included in any of the evidence bases for this evidence report, the group comparability score must have been ≥5. In other words, ECRI required that all studies included in the evidence bases for each of the key questions demonstrate that reasonable efforts were made to ensure that the included studies were protected from selection bias.

### Decision Point 2 Potentially Conclusive?

Decision Point 2 provides a mechanism by which one can define the kinds of results that are required before one can have any hope at all of drawing an evidence-based conclusion. In essence, this decision point involves the evaluation of the statistical power of the overall evidence base and each of its constituent studies. Armitage and Berry(48) provide a mechanism by which one can create a priori decision rules that define what “potentially conclusive” findings are. Consider Figure 3. Four of the findings in this figure are conclusive (A to D). Only finding E is inconclusive.

Figure 3 Conclusive and Inconclusive Findings

Dashed Line = Threshold for a clinically significant difference

Figure 3. Conclusive and Inconclusive Findings

Finding A shows that the treatment is both statistically and clinically significantly more effective than placebo. Finding B shows that Treatment A is statistically significantly more effective than placebo but it is unclear whether this difference is clinically significant. Finding C shows that Treatment A is statistically significantly more effective than placebo but this difference is not clinically significant. Finding D shows that it is unclear whether there is a meaningful difference in efficacy between Treatment A and placebo, but regardless, this difference is not clinically significant. Finding E shows that it remains unclear whether Treatment A is more effective than placebo, but it is also unclear whether this difference is clinically important. This latter finding is thus inconclusive.

For this evidence report, we had decided that an evidence base would be considered potentially conclusive if the summary effect size estimate obtained from a meta-analysis met any of condition A to D in Figure 3. If a quantitative summary effect size estimate could not be obtained, then at least one included study in the relevant evidence base would have to meet one of conditions A to D.

Given the low quality of the evidence base, the limited data for each outcome, and the absence of reporting of measures of variance in the included studies, we did not calculate any within-study effect sizes for this report.

### Decision Point 3 Quality of Evidence Base

Decision Point 3 provides a mechanism by which one can stratify the overall quality of the evidence base that one has established into one of three levels; high, moderate, or low^1^ quality. From this point onward, high, moderate, and low quality evidence bases pass through different pathways of the algorithm. Thus, the quality of an evidence base acts as an important moderator of both the stability and strength-of-evidence ratings that are ultimately assigned to our quantitative and qualitative findings.

1 Low quality refers to an evidence base that is of “lowest acceptable” quality. Remember that studies with fatal flaws have been excluded at Decision Point 1 and are not included in the evidence base.

As is the case for Decision Point 1, the a priori decision rules for Decision Point 3 depend on the method by which one chooses to measure study quality. For example, one may decide that an evidence base with a median quality score measured using a predefined study quality scale that falls above a predefined threshold will be considered as high quality. Likewise, one may decide that an evidence base with a median quality score that falls below a different predefined threshold is low quality.

For this evidence report, our categorization of the quality of the evidence base for Key Question 3 was based on the median of the overall quality scores obtained using ECRI’s checklist for controlled trials (Appendix C). The ranges of median scores that determined whether an evidence base was of high, moderate, or lowest acceptable quality used in this evidence report are presented in Table 10. The overall quality of the evidence relevant to Key Question 3 was judged to be low. (See Figure 5)

Table 10 Quality of Evidence Base

Question # | Instrument | Highest Quality | Moderate Quality | Lowest Quality
All outcomes for all questions | ECRI Controlled Trials Checklist | >8.4 | >6.7 to ≤8.3 | <5

Figure 5 Low-Quality Section of ECRI Strength of Evidence

Figure 5. Low-Quality Section of ECRI Strength of Evidence

### Decision Point 4 Reporting Allows Quantitative Analysis to be Performed?

When poor reporting does not allow one to calculate an accurate effect size estimate for all of the available studies that have addressed a key question, one must make a decision about whether to perform a meta-analysis of only a subset of the overall evidence base or whether to abandon a quantitative analysis of the available data altogether.

For this evidence report, it was decided that a quantitative analysis would be performed if an accurate effect size estimate was available from ≥50% of the available studies. In addition, it was decided that if an accurate effect size estimate could be obtained from ≥50% of the available studies, we would only attempt meta-analysis of the available data if this data came from at least three studies. Consequently, if an evidence base was comprised of fewer than three studies, we would not pool the data using meta-analysis. Instead, the assessment of such an evidence base would be aimed at drawing a qualitative conclusion.

Because the studies utilized for Key Question 3 of this Evidence Report were not of high quality, and because we did not have 3 or more studies addressing the same outcome, we did not consider any quantitative analyses appropriate. Had the quality and quantity of analyzable data been sufficient, we would have used the covariates listed in Table 11 in meta-regression analyses:

Table 11 Covariates for Meta-Regression Analyses

Type of Covariate | Covariate | Continuous/Categorical
Patient characteristics | Differential distribution of demographics | Categorical
| Differential distribution of comorbid conditions | Continuous
Intervention | Method of vertebral axial decompression (VAX-D) | Categorical
| Method of vertebral axial decompression (Other) | Categorical
| Number of sessions | Continuous
| Time of each session (minutes) | Continuous
Study design | Randomized | Categorical

For details regarding the remainder of the ECRI protocol for assessing stability of quantitative estimates and robustness of qualitative estimates, please see the paper by Treadwell et al.(43)

Figure 4 General Section of ECRI Strength-of-Evidence Algorithm (Decision Points 1 through 3)

Figure 4. General Section of ECRI Strength-of-Evidence Algorithm (Decision Points 1 through 3)