# Excluded Studies

No retrieved studies were excluded.