# Literature Search Methods

## Electronic Database Searches

The following databases have been searched for relevant information:

Database | Date limits | Platform/provider
CINAHL | 1982 through January 2007 | OVID
The Cochrane Central Register of Controlled Trials (CENTRAL) | Inception through 2006, Issue 4 | http://www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Inception through 2005, Issue 4 | http://www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Inception through 2005, Issue 4 | http://www.thecochranelibrary.com
CRISP | Searched January 2007 | http://crisp.cit.nih.gov/crisp/crisp_query.generate_screen
Database of Abstracts of Reviews of Effects (DARE) | Inception through 2005, Issue 4 | http://www.thecochranelibrary.com
ECRI Health Devices Alerts | 1977 through January 2007 | ECRI
ECRI Health Technology Forecast | Inception through January 2007 | ECRI
ECRI Healthcare Standards | 1975 through January 2007 | ECRI
ECRI International Health Technology Assessment (IHTA) | Inception through January 2007 | ECRI
ECRI Library Catalog | Inception through January 2007 | ECRI
ECRI TARGET (Technology Assessment Resource Guide for Emerging Technologies) | Inception through January 2007 | ECRI
Embase (Excerpta Medica) | 1974 through January 2007 | OVID
Health Technology Assessment Database (HTA) | Inception through 2005, Issue 4 | http://www.thecochranelibrary.com
MEDLINE | 1966 through January 2007 | OVID
metaRegister of Controlled Trials (mRCT) | Searched January 2007 | http://www.controlled-trials.com/mrct/
PubMed (PreMEDLINE, Publisher) | 1966 through January 2007 | http://www.pubmed.gov
U.K. National Health Service Economic Evaluation Database (NHS EED) | Inception through 2006, Issue 4 | http://www.thecochranelibrary.com
U.S. Centers for Medicare & Medicaid (CMS) Web site | Searched January 2007 | http://www.cms.gov
U.S. Food and Drug Administration (FDA) Web site | Searched January 2007 | http://www.fda.gov
U.S. National Guideline Clearinghouse™ (NGC™) | Inception through January 2007 | http://www.ngc.gov
U.S. National Library of Medicine (NLM) Catalog | Searched January 2007 | http://gateway.nlm.nih.gov

## Search Strategies

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across Embase, Medline, and PsycINFO. A parallel strategy was used to search the databases comprising the Cochrane Library.

## Medical Subject Headings (MeSH), Emtree, PsycINFO and Keywords

### Conventions

OVID
$: truncation character (wildcard)
exp: “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy).
.de.: limit controlled vocabulary heading
.fs.: floating subheading
.hw.: limit to heading word
.md.: type of methodology (PsycINFO)
.mp.: combined search fields (default if no fields are specified)
.pt.: publication Type
.ti.: limit to title
.tw.: limit to title and abstract fields

PubMed
[mh]: MeSH heading
[majr]: MeSH heading designated as major topic
[pt]: Publication Type
[sb]: Subset of PubMed database (PreMedline, Systematic, OldMedline)
[sh]: MeSH subheading (qualifiers used in conjunction with MeSH headings)
[tiab]: keyword in title or abstract
[tw]: Text word

## Topic-specific Search Terms

Axial decompression
- Accuspina
- Accu-spina
- VAX-D
- Vertebral axial decompression

Spinal
- Back
- Intervertebr$
- Lumbar
- Spinal
- Vertbra$

Traction
- Automat$
- Computer$
- Motor$
- Powered
- Traction
- Traction therapy/

Adverse Events
- Ae.fs.
- Co.fs.
- Adverse
- Complicat$
- Error$
- Hazard$
- safety

CINAHL/Embase/Medline

English language, human

Set Number | Concept | Search statement
1 | Axial decompression | VAX-D or (vertebral adj axial adj decompression).tw. or Accu-Spina
2 | Traction | (exp traction therapy/or traction$.tw.) and (automat$ or computer$ or powered or motor$)
3 | Spinal | 2 and (back or lumbar or vertebra$ or intervertebr$ or spinal)
4 | Combine sets | 1 or 3
5 | Limit by publication type | 4 not ((letter or editorial or news or comment or case reports or review or note or conference paper).de. or (letter or editorial or news or comment or case reports or review).pt.)
6 | Eliminate overlap | Remove duplicates from 5
7 | Limit by methodology | 5 and ((Randomized controlled trials or random allocation or double-blind method or single-blind method or placebos or cross-over studies).de. or placebo$.mp. or random$.ti. or crossover$.mp. or cross over.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (blind$ or mask$ or sham$)).mp. or latin square.mp. or ISRTCN)
8 | Adverse events | 5 and (hazard$ or adverse$ or complication$ or safety or error$ or (co or ae).fs.)

Medline (PubMed) – 1/1/66 through 12/13/05

English language

Set Number | Concept | Search statement
1 | | (back OR disc* OR disk* OR spine OR spinal OR vertebra* OR intervertebral) AND (decompress* OR traction*) AND (automat* OR computerised OR computerized OR motorised OR motorized OR powered)
2 | | “VAX-D” OR “vertebral axial decompression”
| | “internal disc decompression” OR “internal disk decompression” OR “kinetic decompression mobilisation” OR “kinetic decompression mobilization”
3 | Limit by publication type | #2 NOT (letter[pt] OR editorial[pt] OR news[pt] OR comment[pt] OR case reports[pt])
4 | Limit to human | #3 AND (humans[mh] OR premedline[sb] OR publisher[sb])
5 | Limit by language | #4 AND English[la]
6 | Limit by methodology | #5 AND (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized controlled trials[mh] OR random allocation[mh] OR double-blind method[mh] OR single-blind method[mh] OR ISRCTN* OR clinical trial[pt] OR clinical trials[mh] OR research design[mh:noexp] OR comparative study[mh] OR evaluation studies[mh] OR follow-up studies[mh] OR prospective studies[mh] OR cross-over studies[mh] OR meta-analysis[mh] OR meta-analysis[pt] OR outcomes research[mh] OR multicenter study[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR ((singl*[tw] OR doubl*[tw] OR trebl*[tw] OR tripl*[tw]) AND (mask*[tw] OR blind*[tw])) OR “latin square” OR placebos[mh] OR placebo* OR random* OR “control group” OR prospective* OR retrospective* OR volunteer* OR sham OR “meta-analysis”[tw] OR cohort)
7 | Adverse events | #5 AND (co[sh] OR ae[sh] OR safety OR hazard* OR recall* OR complication* OR adverse* OR error*)

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI’s collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)