# Results

## Methods Used by the Compendia

Information on the methods used by the compendia is summarized in Tables 1a–1f. The tables are based on information obtained from published versions of the compendia, as well as from interviews with compendia editors. A draft of each compendium’s table entries was reviewed by the compendium’s editor. Comments and corrections from the editor were incorporated into the final tables.

Written information describing the editorial policies of the compendia was found in each compendium, usually in the front matter of printed volumes. Electronic publications were less consistent in where this information could be found. In one instance, the current print edition’s methods were noted by the editor to be obsolete, with current methods accurately described on the web site (USP-DI2). Another compendium made available an unpublished document that described the methods for evidence identification and evaluation in greater detail than the ordinarily available information (AHFS-DI1).

We evaluated all versions easily available to us, including print and electronic versions (Table 1a); however, many compendia publish data in multiple electronic formats. We chose a single electronic version to evaluate for each compendium. Our choice was guided by timeliness of access (we preferred on-line versus a mailed CD-ROM) and cost (we used existing institutional licenses when available). Different electronic platforms had different update cycles varying from daily to quarterly; a quarterly update cycle would result in as much as a 3-month delay for a user to see updated information.

We gleaned the stated purposes of the compendia from introductory published material and paraphrase these in Table 1b. None of the compendia published a “statement of purpose” explicitly labeled as such; however, all had descriptions of their intended use, users, and scope that seemed to set forth their purpose. In addition, AHFS-DI1 had a lengthy description of its history that puts the purpose of this publication in historical context.

The scope of pharmaceutical products covered varied across compendia, particularly with regard to inclusion of non-prescription (OTC) and investigational drugs, and non-U.S. drugs. The compendia generally provided at least the same scope of information on each drug as is required for FDA labeling; some included much more information.

All of the compendia include non-FDA approved indications (Table 1b). They vary in their approach to indicating the off-label use: AHFS-DI uses † (dagger sign; although # [number sign] appears in the on-line HTML-format document); Clinical Pharmacology uses † (dagger sign); USP-DI uses [ ] (square brackets); DRUGDEX uses the phrase “Non FDA-labeled indications”; Facts & Comparisons uses "unlabeled use"; and NCCN provides no indication of off-label use. Most of the compendia had criteria for the conditions under which a non-FDA approved indication would be included. We queried editors regarding how such decisions were made, and in all cases the decision to include a non-FDA approved indication required a judgment by editorial staff regarding the quality and quantity of evidence, and the magnitude of benefit versus harms. In addition, several editors mentioned that a high degree of interest or evidence of use in practice would also be considered in deciding whether to include an off-label listing, particularly in the case of an equivocal indication, where the editorial decision would be to remain silent rather than list an indication that would be qualified as equivocal.

The policy on equivocal evidence (Table 1f) is not clear; however, the scales used for rating evidence and for grading recommendations (Table 1d) were clearly articulated for four of the six compendia. These scales have important implications for the latitude editors may exercise in listing non-FDA approved indications based on equivocal evidence. For example, DRUGDEX7 includes an efficacy rating of Class IIb (Evidence is inconclusive) which can be used to qualify recommendations of strength IIa (Recommended in some cases) or III (Not recommended). Similarly, USP-DI2 uses the same underlying grades, but publishes “Acceptance not established” or “Not accepted.” AHFS-DI1 and NCCN9 have evidence rating schemes and editorial policies that would allow a non-approved indication that can be qualified as equivocal. Facts & Comparisons8 has a scale for grading recommendations, but commented that in the particular situation of non-labeled indications where evidence is equivocal, the de facto editorial policy is to remain silent; the “Not recommended” category is rarely used. Clinical Pharmacology10 does not currently have rating systems in place to qualify a listed indication as based on equivocal evidence and also endorsed a de facto policy of silence.

The explicitness with which recommendations were linked to supporting evidence (Table 1f) varied a great deal across compendia. We regarded an explicit link as having been made only when specific citations to literature (published or unpublished) were provided – we did not interpret a rating of evidence as an explicit link, since the specific data could not be identified. Citations were present only in electronic versions.

Validity assessment was a component of the editorial process for each of the compendia; however, little description of this process was provided in published material. In interviews, editors described the critical appraisal process used by editorial staff. These processes were most clearly articulated by the Thomson MICROMEDEX2, 7 and AHFS-DI1 editors; in addition, AHFS-DI provided a detailed written description of its evidence evaluation process that includes ample documentation of recent methodological literature.

Staffing and conflict of interest policies are described in Table 1e.

Table 1a General description of compendia

Compendium | AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Publisher | American Society of Health-System Pharmacists | Gold Standard, Inc. | Thomson MICROMEDEX | Wolters Kluwer Health | National Comprehensive Cancer Network | Thomson MICROMEDEX
Inception | 1959 | 1994 | ~1977 | 1947 | 2004 | 1980
Print version, update cycle | Annual, selected monograph updates offered on-line as available | NA | NA | Annual Updates monthly (loose-leaf version only) | At least annual or when new evidence reported or new FDA approvals | Annual, selected monograph updates offered on-line
Edition assessed | 2005 | NA | NA | 2006 | NA | 2005
Electronic version, update cycle | On-line, CD-ROM, PDA Updated continuously | On-line, Intranet, CD-ROM Updates continuous (on-line), monthly (Intranet), or quarterly (CD-ROM) | On-line, CD-ROM Updated weekly (on-line) or quarterly (CD) | On-line, CD-ROM Updates monthly (NB – now updated continuously) | Web-only Updated continually | Web CD-ROM Updates daily (Update Website), quarterly (via Healthcare Series, CD), or monthly (flatfiles)
Date accessed and source | 2/17/06 Institutional subscription (Stat!Ref) | 1/19/06 Institutional subscription | 1/20/2006 Institutional subscription | 2/17/06 Drug Facts & Comparisons database in Facts & Comparisons 4.0 | 2/17/06 Free access via internet | 1/18/2006 Individual subscription
Additional information | Gerald McEvoy (Editor in Chief) Olin Welsh, Jr. (Assoc. Editor) | MaryAnne Hochadel, PharmD, BCPS (Editor In Chief) | Lauri Moore (Sr. Dir. of Editorial Operations) Jan Sbarbaro (Counsel) | Renee Wickersham, (Sr. Managing Ed.) Cathy Meives, PharmD (Director, Clinical Information) | Joan McClure (Sr. VP of Clinical Info. and Publications) | Lauri Moore (Sr. Dir. of Editorial Operations) Jan Sbarbaro (Counsel)

Table 1b Purpose of compendia as stated and vis-à-vis unlabeled uses

Compendium | AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Stated purpose | “To provide an evidence-based foundation for safe and effective drug therapy” | “To provide [usable, concise] information on U.S. FDA-approved drugs including prescription and non-prescription (OTC) pharmaceuticals” | “To deliver unbiased drug information for those who prescribe, order, dispense, or administer medications” | To provide “timely, accurate, comprehensive, unbiased, comparative information on prescription and non-prescription medications” to “pharmacists and other health care professionals” | “To support decision-making about the appropriate use of drug and biologic therapy in treating patients with cancer” | To provide complete, yet concise, well-documented information on the “safe and effective use of medication once it was prescribed” for clinicians who prescribe, order, dispense, or administer medications
Scope | Comprehensive U.S. prescription and OTC drugs and biologics | Comprehensive U.S. prescription and OTC drugs; selected investigational drugs and dietary supplements | Comprehensive U.S. and non-U.S. prescription, OTC, and investigational drugs | Comprehensive U.S. prescription, OTC, and investigational drugs (and Canadian trade names) | All anticancer drugs recommended in NCCN Clinical Practice Guidelines in Oncology (NB – these guidelines are estimated to cover 97% of patients with cancer) | Comprehensive U.S. prescription drugs, including U.S. and Canadian trade names
Condition for non-FDA approved indications | Included when supported by evidence “in published medical literature and medical practice” | Included when the use represents current practice and a dosage regimen has been established and documented for the indication. Generally referenced to original clinical research. | Included | Included if “legitimate” and “appropriate” | Included only if included in NCCN Clinical Practice Guidelines in Oncology | Included

Table 1c Methods for evidence identification by drug compendia

Compendium | AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Monograph updating interval | Max: 3–5 years Min: 4–6 weeks | Max: 2 years Min: 1 week | Max: None Min: 6 weeks | Max. None Min: 1 month | Max: 1 year Min: 4–8 weeks | Max: None Min: 6 weeks
Methods to search for evidence | Continuous surveillance of multiple evidence sources | Continuous surveillance of multiple evidence sources | - Weekly automated searches of medical literature - Daily review of (1) key med journal TOCs and (2) alerts from FDA, NIH, CDC, etc. | Continuous surveillance from multiple evidence sources | Literature searches done yearly by staff; supplemented by suggested citations of 19 member inst. plus Clinical Practice Guideline panel members | See DRUGDEX
Sources | - Drug and medical information databases e.g., PubMed, Toxline, www.cancer.gov, www.guidelines.gov, The Cochrane Library, MedWatch) - Relevant medical journals - Government, professional association and industry reports - Routine monitoring of major peer-reviewed medical journals and bibliographic databases | - Official FDA-approved drug label - Primary medical and pharma journals - Abstracting services - Reference texts - Drug compendia - Pharmacology texts - Herbal and Alt Medicine texts - Medical texts - Special resource texts -Drug interaction texts -Nutrition and IV therapy texts | - Drug and medical information databases e.g., PubMed, Toxline, www.cancer.gov, www.guidelines.gov, The Cochrane Library, MedWatch) - Relevant medical journals | - Drug and medical information databases e.g., PubMed, Ovid - Relevant medical journals and textbooks - Government, professional association and industry reports - Routine monitoring of major peer-reviewed medical journals and bibliographic databases | - Primary evidence: Ovid/PubMed, journals, professional association meeting abstracts - Secondary and tertiary: textbooks, websites | See DRUGDEX
Criteria for selecting evidence | Emphasis placed on well-designed, controlled studies, published meta-analyses and systematic reviews, cost-effectiveness analyses | Phase III or IV clinical investigation in the U.S.; lower level evidence at discretion of editorial staff | Designed to be broad; emphasis placed on well-designed, controlled studies, but may include case reports | Well designed, English-language Phase II, III, or IV clinical investigation in the U.S. or meta-analyses; ≥ 30 subjects, ≤ 5 years old; no case reports or animal data | Per NCCN Clinical Practice Guideline panels | Emphasis placed on well-designed, controlled studies; does not generally include case reports

Table 1d Methods for evidence evaluation by drug compendia

Compendium | AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Process of validity assessment | Assessment involves building evidence table for each study, noting study limitations as described in well-referenced document | Subjective, by editorial staff | - Editorial staff assessment based on accepted techniques (e.g. Cho-Bero instrument (1996)) - External reviewers for off-label oncology or potentially controversial indications or when evidence is equivocal | Subjective, by editorial staff | Subjective, based on expert panel | See DRUGDEX
Use of pre-specified, published criteria for weighing evidence | Yes 1-High strength/quality (good RCT or meta-analysis, or overwhelming observational evidence) 2-Moderate strength/quality (RCT with methodologic limitations, inconsistent or indirect evidence, meta-analysis of heterogeneous RCTs, strong observational evidence) 3-Low strength/quality (observational, case reports, case series, seriously deficient RCTs) 4-Opinion/experience NB – strength of endpoint added at each level for cancer uses | No criteria currently used NB – a system is under development; based on AHRQ publications | Yes A-Meta-analysis of RCTs with homogeneity, or multiple, well-done RCTs involving large numbers of patients B-Meta-analysis of RCTs with heterogeneity, RCTs with small numbers of patients or with methodological flaws, or nonrandomized studies C-Expert opinion or consensus, case reports or case series No Evidence | No Professional judgment | Yes High (RCTs or meta-analysis) Lower (Phase II trials or large cohort studies, ranging to individual practitioner experience) | See DRUGDEX
Grading recommendations | A-Recommended B-Reasonable choice C-Not fully established D-Not recommended (considered inappropriate, obsolete or unproven) | No scale used for grading recommendations NB – a system is under consideration; certain add-on modules (e.g., ACP PIER) include grading for recommendations | Strength of recommendation: I: Recommended IIa: Recommended in most cases IIb: Recommended in some cases III: Not recommended Efficacy: Class I – Effective Class IIa – Evidence favors efficacy Class IIb – Evidence is inconclusive Class III - Ineffective | Professional judgment | 1-High/Uniform 2A-Lower/Uniform 2B-Lower/Non-uniform 3-Any/Major disagreement | Accepted (FDA + off-label) Acceptance not established Not accepted (inappropriate, obsolete, unproven)

Table 1e Staffing and protection from conflict of interest by drug compendia

Compendium | AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Staffing of evidence assembly/synthesis task | Profession staff of drug information analysts and editors (n = 20; mostly pharmacists) | - Professional staff (board-certified) of pharmacists as senior editors (n = 8) - Review by Managing editors (n = 2 pharmacists) - Occasional external review | Clinical professional editorial staff, teams of editors with content expertise track certain drugs/therapeutic areas, monitor evidence, and perform reviews/updates | - Team of 6 clinical editors and 6 pharmacists - Outside pharmacist consultants on contract sometimes used | Prepared by staff, interpreted by disease-specific expert panels (comprised of faculty from NCCN member institutions) | See DRUGDEX
Staffing of monograph preparation | - 20 full-time staff - Occasional use of free-lance writers | - 12 full-time staff - Occasional use of free-lance writers | > 100 full-time staff | 17 technical editors and 4 pharmacists | 20 staff (listed on web page), including 4 MDs, 3 PhDs, 1 PharmD | See DRUGDEX
Staffing of reviews of drug monographs | External (unpaid) | - Internal mostly - External (paid) as needed | External (paid) | - Internal mostly - External (paid; sometimes used) | Reviewers from member institutions (unpaid) | See DRUGDEX
Conflicts of interest disclosure | Staff: Yes Consultants: Yes Reviewers: Yes | Staff: Yes Consultants: Yes Reviewers: No | Disclosure policy: - Not disclosed if board member paid < $25,000 by pharma company - Disclosure if income $25,000-$100,000 -Exclusion if paid >$100,000 | Staff: Yes Consultants: Yes Reviewers: Yes | Staff: Yes Consultants: NA Reviewers: Yes | See DRUGDEX
Funding source, public notification of funding sources | - Funded by subscription and licensing fees only - IRS form 990 publically available - Annual external independent audit reported to membership | Funded by subscription and licensing fees only | Funded by subscription and licensing fees | Funded by subscriptions and data licensing | - Member dues pay staff, operating costs - Industry grants pay distribution costs | Funded by subscriptions

Table 1f Methods for recommendations by drug compendia

Compendium | AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Explicit link between recommendation and supporting evidence | Electronic version only | - Most off-label uses referenced to primary literature - Off-label use review and referencing is a standard part of editorial update process | - Yes - Process involves explicit evidence retrieval | Provided on request (not published) | Yes (in Clinical Practice Guidelines – compendium does not list supporting evidence, but all recommendations in compendium correspond to recommendation in Clinical Practice Guideline) | Web version only
Policy on equivocal evidence | Describe evidence as equivocal; listing vs. silence may depend on evidence of use, perceived interest | - Silence - NB – in absence of an off-label use in indications/dosages section, use may be mentioned | Listing with efficacy rating of IIa or IIb | Silence (“Not recommended” category rarely used) | - Silence usually - NB - Sometimes recommendation listed with less than full consensus (2B or 3); sometimes listed as investigational (clinical trial only) | Listing with “Acceptance not established” or silence (listing may depend on use/interest)
Method for formulating recommendations | - Editors review evidence, draft recommendation; reviewed by other editorial staff - External review for comment | - Editor reviews evidence and drafts recommendation; reviewed by other editorial staff - External review for comment | - Editor reviews evidence and drafts recommendation; reviewed by senior editorial staff - External review for comment | Editor reviews evidence and drafts recommendation; reviewed by other editorial staff | -Panel develops initial draft and circulates to member institutions for comment -Staff collate comments - Panel reconvenes to formulate guidelines - Annual update meetings to review guidelines | See DRUGDEX
Outcomes considered – benefits | Explicitly specified hierarchy of outcomes^*^ for oncology drugs | Implicit | Implicit | Implicit | Explicit | Implicit
Outcomes considered – harms | Emphasis placed on efficacy; harms rarely explicitly considered for oncology drugs NB – Comparative toxicity typically discussed in Uses section when information available from RCTs; adverse effects info available from labeled uses of the drug | Emphasis placed on efficacy; safety also considered in off-label listing if expected or known to be different from labeled safety data | Implicit NB – Strength of Recommendation scale addresses the concept of usefulness (risk-benefit ratio) as well as efficacy | Emphasis placed on efficacy; harms rarely explicitly considered for oncology drugs | - Harms always considered; sometimes are deciding factor in Clinical Practice Guideline recommendations - Harm data not explicitly presented in the compendium | Implicit NB – Acceptance rating scale addresses the concept of usefulness (risk-benefit ratio) as well as efficacy

* Overall survival, cause-specific mortality, quality of life, recurrence/progression/response.

## Studies Identified in the EPC Literature Review

The MEDLINE search identified 1314 potentially relevant citations (Table 1g). An additional 18 unique citations were identified for some topics from the Cochrane Central Registered of Controlled Trials (CENTRAL). Finally, 179 abstracts were identified from the American Society of Clinical Oncology (ASCO) website.

Table 1g Number of citations identified for each agent-cancer combination

Agent | Cancer | MEDLINE, MEDLINE In- Process & Other Non- indexed Citations | CENTRAL | ASCO abstracts
Bevacizumab | Breast | 48 | 4 | 12
Bevacizumab | Lung | 47 | 0 | 19
Oxaliplatin | Breast | 33 | 2 | 9
Oxaliplatin | Lung | 70 | 2 | 37
Irinotecan | Breast | 137 | 1 | 13
Docetaxel | Esophageal/Gastric^*^ | 87 | 5 | 40
Docetaxel | Ovarian | 139 | 4 | -
Gemcitabine | Biliary tract | 57 | - | 3
Gemcitabine | Bladder | 107 | - | 17
Gemcitabine | Ovarian | 407 | - | 7
Rituximab | Chronic lymphocytic leukemia | 149 | - | 15
Erlotinib | Head and neck | 16 | - | 2
Erlotinib | Pancreas | 17 | - | 5
Totals: | | 1314 | 18 | 179

* A combined esophageal and gastric search strategy was used.

The publications thus identified were screened to determine whether they met the EPC inclusion criteria. Results of this screening process are described for each agent-cancer pair below.

## Bevacizumab (Avastin®) for Breast Cancer

Bevacizumab is a humanized monoclonal antibody against vascular endothelial growth factor (VEGF). It is designed to inhibit tumor neovascularization and is not directly cytotoxic. Therefore, it is usually administered in combination with traditional cytotoxic treatments such as chemotherapy, radiation therapy, or hormonal therapy. Bevacizumab is FDA approved for the first-line treatment of metastatic colorectal cancer in combination with 5-fluorouracil (5-FU) chemotherapy. It has also been evaluated for off-label use in breast cancer.

### Systematic Review by EPC

A total of 64 articles and abstracts were identified through the EPC literature search. Of these, 10 met the EPC inclusion criteria.

Table 2a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 1) reports details from each of the 10 studies. The literature review identified seven clinical trials, of which two were Phase III, three Phase II, and two Phase I/II, involving a total of 1330 subjects. An additional 1782 subjects were involved in other types of studies, including a retrospective review to evaluate the risk of arterial thrombotic events (N = 1745; included subjects with breast, colorectal, and lung cancer, with the number of breast cancer subjects unknown) and two clinical research reports focused on the mechanism of action of bevacizumab in breast cancer (N = 37).

Table 2a Study types and outcomes reported – bevacizumab for breast cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 10 | 3112^a^ | 2003–5 | 7 | 2 | 2 | - | 7
Phase III | 2 (20%) | 1177 (38%) | 2005 | 2 | 2 | 2 | - | 2
Phase II | 3 (30%) | 70 (2%) | 2004–5 | 3 | - | - | - | 2
Phase I/II | 2 (20%) | 83 (3%) | 2003–5 | 1 | - | - | - | 1
Other^b^ | 3 (30%) | 1782^a^ (57%) | 2004 | 1 | - | - | - | 2
No. of above published as abstracts | 9 (90%) | 2650^a^ (85%) | 2003–5 | 6 | 1 | 1 | - | 6

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Includes an unclear number of subjects with colorectal and lung cancer.

b Studies of mechanism of action or adverse effects.

Peer-reviewed Phase III trials. The two Phase III studies were the largest clinical trials in this review, and both evaluated tumor response, survival, quality of life (QoL), and adverse effects.14, 15 Neither study reported the impact of the interventions on symptoms.

The study of bevacizumab (15 mg/m^2^ q3wks) plus capecitabine vs capecitabine alone was published in full text in the Journal of Clinical Oncology in February 2005.^15^ The study involved women with heavily-pretreated metastatic breast cancer (80 percent with 1–2 prior regimens for metastatic breast cancer). The addition of bevacizumab significantly increased tumor response (19.8 percent vs 9.1 percent; p = 0.001) but did not influence progression-free survival (the primary endpoint), overall survival, or QoL. Bevacizumab-treated participants had more hypertension requiring intervention (17.9 percent vs 0.5 percent).

The Phase III study of bevacizumab (10mg/m^2^ q 2wks) plus paclitaxel vs paclitaxel alone as first-line treatment in metastatic or locally-recurrent breast cancer was published in abstract form only.14, 16 A 2003 brief summary of this same study published in Clinical Breast Cancer was referenced by the NCCN compendia, but did not meet the EPC inclusion criteria.16 At the 2005 ASCO meeting these data were presented by Dr. K. Miller as part of an oral presentation on bevacizumab and similar therapies (slides publicly available through the ASCO website), but a specific abstract about the trial was not included in the 2005 ASCO abstract book. The abstract was presented at the earlier San Antonio Breast Cancer meeting. The addition of bevacizumab significantly increased tumor response (28.2 percent vs 14.2 percent; p < 0.0001), improved progression-free survival (10.97 vs 6.11 months; p = 0.001), and improved overall survival (p for survival analysis = 0.01). QoL analyses had not been completed at the time of the presentation. Bevacizumab-treated participants had more hypertension requiring intervention (13.3 percent vs 0 percent), proteinuria (2.4 percent vs 0 percent), and nephropathy (0.3 percent and 0 percent). Longer followup is planned for further assessment of the impact of bevacizumab on overall survival.

Peer-reviewed Phase II and I/II trials. Of the five Phase II and I/II trials, one was randomized.17 All were reported in abstract form. Four assessed patients with metastatic breast cancer and one evaluated the use of bevacizumab in the neoadjuvant setting. Co-interventions included erlotinib, docetaxel, letrozole, and “chemotherapy.” Tumor response, defined as complete plus partial responses, ranged from 3 to 11 percent. Survival and QoL data were not presented. Three of five (60 percent) studies discussed adverse effects.

The neoadjuvant study was also the only randomized study; it compared docetaxel plus bevacizumab to docetaxel alone, and the distinction between the two regimens on outcomes was not clear within the abstract. Doses ranged from 3 to 20 mg/m^2^ every 2 to 3 weeks.

### Compendia Listings

Treatment indication and toxicities. Table 2b summarizes the compendia’s discussions of the off-label use of bevacizumab for treatment of breast cancer. Only DRUGDEX and NCCN explicitly stated whether there was an off-label indication for the drug in the setting of this cancer. DRUGDEX stated “level III” – not clearly recommended – and NCCN stated “indicated.” NCCN did not report on toxicities due to bevacizumab. All other compendia, regardless of whether they discussed an off-label indication for breast cancer or not, discussed toxicities, including severity and frequency of adverse effects, and which organs have been reported to be affected. Only USP-DI discussed bevacizumab-related toxicities specifically among patients being treated for breast cancer.

Table 2b Summary of compendia listings – bevacizumab for breast cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | No | Yes | No | Yes | No
Sub-category of indication (accepted or acceptance not established) | - | - | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | - | 2A | -
Stage of cancers | - | - | Metastatic breast cancer | - | Recurrent or metastatic | -
Method of treatment (first line or other) | - | - | Pre-treated patients | - | Other | -
Routes of administration | - | - | IV | - | NR | -
Uses of the agent (monotherapy or combination) | - | - | Monotherapy | - | Combination | -
Comparator discussed (placebo, standard treatment, other agents) | - | - | NR | - | NR | -
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | - | Duration of confirmed response, tumor burden, ECOG status | - | Disease-free survival; overall survival | -
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: Yes Severity: No By organ: Yes Frequency: No | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: No Indication-specific: No Severity: No By organ: No Frequency: No | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | - | 3, 10, or 20 milligrams/kilogram (mg/kg) every 2 weeks | - | 10 mg/kg IV days 1 & 15, cycled every 28 days | -
Number of evidence citations | - | - | 1 (+ 1)^a^ | - | 1 | -
Range of years of citations | - | - | 2001 | - | 2003 | -
Sources of evidence (abstracts/published articles) | - | - | Abstract | - | Abstract | -
Number of abstracts cited [years] | - | - | 1 [2001] | - | 1 [2003] | -
Number of published articles cited [years] | - | - | 1 review [2002] | - | 0 | -
Date of last update | 1/10/2006 | 12/06/2005 | NR | NR | 12/05/20005 | 7/25/2005

a 1 article cited; 1 additional review article included in the reference list.

Studies cited in compendia versus studies identified in EPC review. Only DRUGDEX and NCCN provided any references (Table 2b); one reference was cited by each. Neither of the two references cited by these compendia met the EPC criteria for inclusion, as both were old abstracts (about different studies) with a more recent update available. Neither compendia cited the published full-text Phase III trial of bevacizumab plus capecitabine vs capecitabine alone. Only NCCN cited the Phase III study of bevacizumab plus paclitaxel vs paclitaxel alone, but in doing so referred to an old abstract.

A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 2c.

Table 2c Articles cited by compendia vs. articles identified by EPC – bevacizumab for breast cancer

Reference | EPC | AHFS- DI | USP-DI | DRUGDEX | F & C | NCCN | Clin Pharm | Notes
Reviewed by compendia: | - | No | No | Yes | No | Yes | No | -
Phase III
Miller, 2005^15^ | x
Miller, 2005^14^ | x | | | | | | | Same study
Miller, 2003^16^ | | | | | | x^a^ | | Same study
Phase II
Rugo, 2005^18^ | x
Dickler, 2004^19^ | x
Overmoyer, 2004^17^ | x
Phase I/II
Traina, 2005^20^ | x
Cobleigh, 2003^21^ | x | | | | | | | Same study
Cobleigh, 2001^22^ | | | | x^b^ | | | | Same study
Phase I
(none)
Other
Denduluri, 2005^23^ | x
Skillings 2005^24^ | x
Wedam, 2004^25^ | x
Pegram, 2002^26^ | | | | * | | | | Review

a Not identified by EPC because abstract older than abstract search cut-off and non-ASCO; however, an update of this trial was presented at ASCO by Miller et al. and review of their slides was available for EPC review.

b Not identified by EPC because it is an old abstract with updated abstract in 2003 (See Cobleigh21).

* Non-cited reference.

Recommendations and supporting evidence. DRUGDEX states that there is inconclusive evidence for a clear recommendation of bevacizumab for breast cancer, indicating a recommendation of level III (not clearly recommended) based upon evidence strength B. Its cited reference was a 2001 abstract from Cobleigh,22 a non-randomized Phase II trial with an updated abstract published 2 years later. It specified that the place for bevacizumab is as monotherapy for metastatic breast cancer and stated that more studies are needed.

NCCN cites a 2A indication for bevacizumab in breast cancer, with lower quality evidence, but uniform agreement about this conclusion. It specified that bevacizumab should be used in combination at doses and in patients consistent with the Miller study of bevacizumab plus paclitaxel. Its cited reference was a 2003 abstract of this Phase III trial, which was updated recently, but the update was not cited. No toxicity data are provided, despite clear information about toxicity in the Miller studies.

Summary. Listings of bevacizumab for breast cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Two of the six compendia (DRUGDEX and NCCN) discuss bevacizumab for treatment of breast cancer.
- Specificity of clinical information: DRUGDEX offers a dose range and mentions several outcomes, including duration of response, tumor burden, and ECOG status, but without describing precise estimates of benefit. NCCN cites evidence of improvement in disease-free and overall survival, but does not quantify the magnitude of benefit. NCCN offers specific dosing information for bevacizumab and paclitaxel based on the single cited trial.
- Evidence rating: Both DRUGDEX and NCCN provide explicit evidence ratings for the off-label indication of bevacizumab for breast cancer. DRUGDEX rates the evidence as “inconclusive” based on lower level evidence (RCTs with small numbers of patients or methodological flaws, or nonrandomized studies). It cites one Phase I/II trial and a review article. NCCN lists the off-label use based on “lower” level evidence but with “uniform” consensus (category 2A), citing a single Phase III trial.
- Recommendation statements: DRUGDEX states that use of bevacizumab is “not recommended” based on lower level evidence, which it describes as “inconclusive;” this statement applies to use in previously treated patients with metastatic disease. NCCN endorses the off-label use for first-line treatment of metastatic breast cancer based on lower level evidence, but with uniform consensus (category 2A), citing a single trial.
- Toxicity: Toxicities related to bevacizumab are reported in most of the compendia, but only USP-DI notes toxicities specifically in patients with breast cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include breast cancer as an off-label indication for bevacizumab. It emphasizes well-designed, controlled, published studies, but does not cite the two Phase III studies identified in the EPC review. The last update was 1/17/06, but 2005 data, including the two Phase III trials, are not cited.
- USP-DI specifies that it includes off-label indications, but it does not include breast cancer as an off-label indication for bevacizumab. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff, but it does not cite the Phase III studies identified in the EPC review. The last update was 12/6/05, but 2005 data are not cited.
- DRUGDEX specifies that it includes off-label indications, and it does include breast cancer as an off-label indication for bevacizumab. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites an old narrative review, but does not cite the two Phase III studies identified in the EPC review. The date of the last update is not reported, but 2005 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it does not include breast cancer as an off-label indication for bevacizumab. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite the clinical trials identified in the EPC review that meet these criteria, including two Phase III studies. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is an off-label indication for bevacizumab in breast cancer as per the guideline. The last update was 12/5/05, but 2005 data are not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it does not include breast cancer as an off-label indication for bevacizumab. It emphasizes prospective trials, but does not cite the two Phase III studies or the other clinical trials identified in the EPC review. The last update was 7/25/05, but early 2005 data are not cited.

## Bevacizumab (Avastin®) for Lung Cancer

As stated above, bevacizumab is a humanized monoclonal antibody against VEGF. It is designed to inhibit tumor neovascularization and is not directly cytotoxic. Therefore, it is usually administered in combination with traditional cytotoxic treatments such as chemotherapy, radiation therapy, or hormonal therapy. Bevacizumab is FDA approved for the first-line treatment of metastatic colorectal cancer in combination with 5-FU chemotherapy. It has also been evaluated for off-label use in lung cancer.

### Systematic Review by EPC

A total of 66 articles and abstracts were identified through the EPC literature search. Of these, five met the EPC inclusion criteria. One of the five studies27 had three associated abstracts from the same study presented at the 2004 ASCO meeting.

Table 3a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 2) reports details from each of the five studies. The literature review identified four clinical trials, of which one was Phase II/III, two Phase II, and one Phase I/II, involving a total of 1022 subjects. An additional 1745 subjects were included in a retrospective review to evaluate the risk of arterial thrombotic events (included subjects with breast, colorectal, and lung cancer, with the number of lung cancer subjects unknown).

Table 3a Study types and outcomes reported – bevacizumab for lung cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 5 | 2767^a^ | 2004–5 | 4 | 4 | - | - | 5
Phase II/III | 1 (20%) | 842 (30%) | 2005 | 1 | 1 | - | - | 1
Phase II | 2 (40%) | 140 (5%) | 2004–5 | 2 | 2 | - | - | 2
Phase I/II | 1 (20%) | 40 (3%) | 2005 | 1 | 1 | - | - | 1
Other^b^ | 1 (30%) | 1745a (63%) | 2004 | - | - | - | - | 1
Abstracts | 3 (60%) | 2628^a^ (95%) | 2004–5 | 2 | 1 | - | - | 3

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Includes an unclear number of subjects with colorectal and breast cancer.

b Study of adverse effects.

Peer-reviewed Phase II/III trials. The Phase II/III study was the largest clinical trial in this review.28 It was presented at the ASCO 2005 meeting and has not yet been published in full text. The study evaluated bevacizumab (15 mg/m^2^ q3wks) plus carboplatin (PCB) and paclitaxel vs carboplatin and paclitaxel (PC) in the first-line setting. Participants had stage IIIB or IV non-small cell lung cancer (NSCLC); squamous cell NSCLC was excluded. Tumor response, survival, and adverse effects were evaluated. The impact of the interventions on QoL and symptoms was not reported. A total of 842 subjects were randomized, 436 to PCB and 444 to PC. The addition of bevacizumab significantly increased tumor response (27 percent vs 10 percent; p = 0.0001), progression-free survival (6.4 mo vs 4.5 mo; p < 0.0001), and overall survival (12.5 mo vs 10.2 mo; p = 0.0075). Bevacizumab-treated participants had more grade 4/5 neutropenia (24 percent vs 16 percent), grade 3/4 thromboembolism (3.8 percent vs 3 percent), and hemorrhage (4.1 percent vs 1 percent).

Peer-reviewed Phase II and I/II trials. Of the three Phase II and I/II trials, one was randomized.29 This randomized study by Johnson et al.29 was published in full-text form in 2004 and provided the background data for the Phase II/III study by Sandler et al.28 described above. The predominant differences were that a third arm with bevacizumab at 7.5mg/m^2^ was included, and patients with squamous cell NSCLC were included. These patients with squamous cell NSCLC were later excluded in the Sandler28 study due to an increased risk of adverse effects in this sub-population.

Herbst and colleagues evaluated bevacizumab plus erlotinib in a non-randomized Phase I/II study published in 2005.^27^ Participants had heavily pre-treated non-squamous NSCLC, and 20 percent partial responses were identified. This combination is undergoing further study. Raefsky and colleagues presented a 2005 ASCO abstract of bevacizumab plus irinotecan, carboplatin, and radiotherapy in limited stage small cell lung cancer (SCLC).30 This combination was also deemed appropriate for further study.30

### Compendia Listings

Treatment indication and toxicities. Table 3b summarizes the compendia’s discussions of the off-label use of bevacizumab for treatment of lung cancer. Five of the six compendia explicitly stated there was an off-label indication for the drug in the setting of this cancer. All compendia, regardless of whether they discussed an off-label indication for breast cancer or not, discussed toxicities, including severity and frequency of adverse effects, and which organs have been reported to be affected. All but AHFS-DI and Clinical Pharmacology discussed bevacizumab-related toxicities specifically among patients being treated for lung cancer.

Table 3b Summary of compendia listings – bevacizumab for lung cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | Yes | Yes | Yes | Yes | Yes
Sub-category of indication (accepted or acceptance not established) | - | Accepted | Evidence favors efficacy Recommendation: Adult, Class IIb Strength of Evid: Adult, Category B | NR | Category 2A – lower level evidence and uniform consensus that the recommendation is appropriate | NR
Stage of cancers | - | Non-squamous non small cell lung cancer, advanced/metastatic, first-line treatment | Advanced non-squamous NSCLC | “Non-small cell lung cancer” | Non-squamous NSCLC: no history of hemoptysis, no CNS metastases, no ongoing therapeutic anticoagulation | Advanced and metastatic
Method of treatment (first line or other) | - | First line – in combination | First line – in combination | NR | First line – in combination | NR
Routes of administration | - | IV | NR | IV | NR | IV
Uses of the agent (monotherapy or combination) | - | Combination | Combination | Combination with carboplatin and paclitaxel | Combination | Combination
Comparator discussed (placebo, standard treatment, other agents) | - | None | Same combination, but with placebo instead of bevacizumab | NR | Same combination, but without bevacizumab | Same combination, but placebo instead of bevacizumab
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | Response rates, time to progression, and overall survival | Response rates, time to progression, and overall survival | NR | Response rate Progression-free survival Median survival | Response rate Progression-free survival Median survival
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: Yes Severity: No By organ: Yes Frequency: No | Overall: Yes Indication-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | 5 mg per kg over 90 min every 14 days | No | No | No | Yes for bevacizumab + paclitaxel + carboplatin
Number of evidence citations | - | 3 | 2 | 1 | 2 | 1
Range of years of citations | - | 2004–2005 | 2004–2005 | 2004 | 2004–2005 | 2005
Sources of evidence (abstracts/published articles) | - | 2 published article + 1 abstract | 1 published article + 1 abstract | 1 published article^a^ | 1 published article + 1 abstract | Abstract
Number of abstracts cited [years] | - | 1 [2005] | 1 [2005] | 0 | 1 [2005] | 1 [2005]
Number of published articles cited [years] | - | 2 [2004–2005] | 1 [2004] | 1 [2004] | 1 [2004] | 0
Date of last update | 1/10/2006 | 12/06/2005 | NR | NR | 11/22/05 | 7/25/2005

a Listed erroneously in evaluated version of drug monographs as “package insert.”

Studies cited in compendia versus studies identified in EPC review. Only USP-DI, DRUGDEX, and NCCN provided clear references (Table 3b); 2 to 3 references were cited by each compendium. All three compendia cited the Sandler28 Phase II/III trial and its preliminary study, published by Johnson et al.29 USP-DI also cited the Herbst Phase I/II study of bevacizumab plus erlotinib.27 All of the cited references were also identified in the EPC review. Facts & Comparisons erroneously cited the package insert; however, the editor informed us that the indication was based on the preliminary study published by Johnson et al.29 Clinical Pharmacology was silent regarding references; while AHFS-DI did not include this off-label indication or list references.

A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 3c.

Table 3c Articles cited by compendia vs. articles identified by EPC – bevacizumab for lung cancer

Reference | EPC | AHFS-DI | USP-DI | DRUGDEX | F & C | NCCN | Clin Pharm
Reviewed by compendia: | - | No | Yes | Yes | Yes | Yes | Yes
Phase II/III
Sandler 2005^28^ | x | | x | x | | x | x
Phase II
Raefsky, 2005^30^ | x
Johnson, 2004^29^ | x | | x | x | x^a^ | x
Phase I/II
Herbst, 2005^27^ | x | | x
Phase I
(none)
Other
Skillings, 2005^24^ | x

a Johnson, 2004 was supposed to have been cited, but the package insert was erroneously substituted as the citation in the drug monograph we reviewed.

Recommendations and supporting evidence. USP-DI states that there is acceptable evidence for an off-label indication of bevacizumab for lung cancer in the first-line setting. The profile of the recommended patient population follows that of the Sandler28 study. The recommended dose is 5 mg per kg over 90 min every 14 days in combination with other chemotherapies, not the 15mg/m^2^ every 3 weeks used in the Sandler28 study.

DRUGDEX provides a recommendation of level IIb based upon evidence strength B. The profile of the recommended patient population follows that of the Sandler28 study, and it is stated that the agent should be used in combination with other chemotherapies; a dose is not recommended.

Facts & Comparisons provides an off-label indication for NSCLC without further specification about the patient population. It recommends that bevacizumab be used in combination with paclitaxel and carboplatin; a dose is not recommended.

NCCN cites an indication as Category 2A based on lower level evidence and uniform consensus that the recommendation is appropriate. The profile of the recommended patient population follows that of the Sandler28 study, and it is stated that the agent should be used in combination with other chemotherapies; a dose is not recommended. Toxicity data are provided.

Clinical Pharmacology provides an off-label indication for advanced and metastatic NSCLC without further specification about the patient population. It recommends that bevacizumab be used in combination with paclitaxel and carboplatin; dosing is specific to this combination.

Summary. Listings of bevacizumab for lung cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Five of the six compendia (all except AHFS-DI) discuss bevacizumab for treatment of NSCLC.
- Specificity of clinical information: All five of the compendia listing this recommendation describe use in advanced or metastatic NSCLC. All five recommend combination therapy, although only two describe specific combination regimens (Facts & Comparisons and Clinical Pharmacology). Four of the five (all but Facts & Comparisons) describe outcomes expected to be impacted (similarly listed as response rate, time to progression, and overall survival), and three of the five (DRUGDEX, NCCN, and Clinical Pharmacology) present quantitative estimates of the magnitude of benefit.
- Evidence rating: Only two compendia (DRUGDEX and NCCN) provide explicit evidence ratings for the off-label indication of bevacizumab for NSCLC. Evidence is rated in the second tier by both. All five compendia listing this indication cite at least one study; four cite the same Phase III study. None of the five compendia cites more than three studies.
- Recommendation statements: USP-DI lists the off-label use under the “Accepted” category. DRUGDEX lists the recommendation as IIb (“Recommended in most cases”), while NCCN describes uniform consensus that the indication is appropriate. Facts & Comparisons and Clinical Pharmacology make no further qualification of the off-label use of bevacizumab in NSCLC.
- Toxicity: Toxicities related to bevacizumab are reported in all of the compendia, and four (USP-DI, DRUGDEX, Facts & Comparisons, and NCCN) note toxicities specifically in patients with NSCLC.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice are more consistent for bevacizumab in lung cancer than for the same agent in breast cancer. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include lung cancer as an off-label indication for bevacizumab. It emphasizes well-designed, controlled, published studies, but does not cite the published Phase II/III study identified in the EPC review. The last update was 1/10/06, but 2005 data, including the Phase II/III study, are not cited.
- USP-DI specifies that it includes off-label indications, and it does include lung cancer as an off-label indication for bevacizumab. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. It cites the one Phase III study identified in the EPC review, as well as two Phase I/II or II studies. The last update was 12/6/05; 2005 data are cited.
- DRUGDEX specifies that it includes off-label indications, and it does include lung cancer as an off-label indication for bevacizumab. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites the one Phase III study and one of the preliminary Phase II studies identified in the EPC review. The date of the last update was not reported; 2005 data are cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes lung cancer as an off-label indication for bevacizumab. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite any of the clinical trials identified in the EPC review that meet these criteria, including the Phase III study. We were informed by the editors that one Phase II study was supposed to have been cited, but that the package insert was erroneously substituted in the version we reviewed. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is an off-label indication for bevacizumab in lung cancer as per the guideline. The last update was 11/22/05, and 2005 data are cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes lung cancer as an off-label indication for bevacizumab. It emphasizes prospective trials, but cites only one of the four clinical trials identified in the EPC review (the 2005 Phase III study), omitting the earlier Phase I/II and Phase II studies. The last update was 7/27/05, and 2005 data are cited.

## Oxaliplatin (Eloxatin®) for Breast Cancer

Oxaliplatin is a third-generation platinum analog. Oxaliplatin is a non-cell cycle specific, alkylating chemotherapeutic drug that impairs DNA synthesis by forming platinum-DNA crosslinks that inhibit DNA replication and transcription. Its activity and toxicity profiles differ from both cisplatin and carboplatin, and thus it lacks cross-resistance with these compounds. Unlike cisplatin or carboplatin, oxaliplatin is not associated with significant renal or auditory toxicity, and hematological toxicity is usually mild. Oxaliplatin has a large spectrum of anticancer activity and has been used in combination with many other chemotherapy agents.

Oxaliplatin is FDA approved as a second-line therapy for the treatment of metastatic colorectal cancer; a first-line treatment for advanced colorectal cancer; and an adjuvant treatment for stage III colorectal cancer. It has also been evaluated for off-label use for breast cancer.

### Systematic Review by EPC

A total of 44 articles and abstracts were identified through the EPC literature search. Of these, nine met the EPC inclusion criteria. Eight of the nine were abstracted. One Phase II study of oxaliplatin by continuous infusion published in 1990 could not be obtained for abstraction.

Table 4a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 3) reports details from each of the eight studies. The literature review identified eight prospective clinical trials, of which one was a Phase II/III study and seven were Phase II studies. A total of 357 subjects were involved.

Table 4a Study types and outcomes reported – oxaliplatin for breast cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 8 | 357 | 2002–5 | 8 | 4 | - | 4 | 8
Phase II/III | 1 (12%) | 137 (38%) | 2004 | 1 | 1 | - | - | 1
Phase II | 7 (88%) | 220 (62%) | 2002–5 | 7 | 3 | - | 4 | 7
Phase I/II | - | - | - | - | - | - | - | -
Other | - | - | - | - | - | - | - | -
No. of above published as abstracts | 3 (38%) | 198 (55%) | 2004–5 | 3 | 2 | - | 2 | 3

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

Peer-reviewed Phase II/III trials. One Phase II/III study was identified.31 This was a randomized study of oxaliplatin plus 5-FU vs vinorelbine plus 5-FU in women with previously-treated advanced or metastatic breast cancer. All subjects had received taxane and doxorubicin based chemotherapy in the past. The vinorelbine arm was chosen as an established comparator intervention in this clinical setting. The oxaliplatin dose was 130mg/m^2^ every 3 weeks. The study was prematurely closed after accrual of 137 subjects due to recruitment difficulties. Oxaliplatin-based chemotherapy was as efficacious as the vinorelbine-based chemotherapy in terms of tumor response, time to progression, and overall survival. The oxaliplatin-based intervention caused significantly less neutropenia (13 percent vs 78 percent; p < 0.001), mucositis (12 percent vs 32 percent; p = 0.0043), and neurosensory changes (0 percent vs 7.5 percent; p = 0.0279).

Peer-reviewed Phase II trials. Of the seven Phase II trials, none was randomized. Oxaliplatin doses ranged from 85 to 130mg/m^2^. Monotherapy demonstrated activity in heavily-pretreated metastatic breast cancer patients; studies of combination therapy with other chemotherapeutics were recommended.32 Co-interventions studied were capecitabine, 5-FU, and gemcitabine. All studies involved subjects with heavily-pretreated metastatic breast cancer. A non-randomized parallel Phase II study of two different dosing schedules, every 2 or 3 weeks in combination with gemcitabine, showed equal efficacy of both schedules.33

Peer-reviewed Phase I and other studies. No studies in these categories were identified.

### Compendia Listings

Treatment indication and toxicities. Table 4b summarizes the compendia’s discussions of the off-label use of oxaliplatin for treatment of breast cancer. Both Clinical Pharmacology and DRUGDEX explicitly stated an off-label indication for the drug in this cancer. All the compendia, regardless of whether they discussed an off-label indication for breast cancer or not, discussed toxicities, including severity and frequency of adverse effects, and which organs have been reported to be affected. None discussed oxaliplatin-related toxicities specifically among patients being treated for breast cancer.

Table 4b Summary of compendia listings – oxaliplatin for breast cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | No | Yes | No | No | Yes
Sub-category of indication (accepted or acceptance not established) | - | - | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | - | - | Advanced or metastatic
Stage of cancers | - | - | Prior taxane and anthracycline treatment | - | - | Taxane- and anthracycline-retreated advanced and metastatic breast cancer
Method of treatment (first line or other) | - | - | NR | - | - | NR
Routes of administration | - | - | NR | - | - | IV
Uses of the agent (monotherapy or combination) | - | - | Combination with 5-FU | - | - | Combination with fluorouracil
Comparator discussed (placebo, standard treatment, other agents) | - | - | None | - | - | None
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | - | Response rate | - | - | Time to progression, median survival
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | - | 130 mg/m^2^ IV on day 1 plus 5-FU 1000 mg/m^2^/d on days 1–4 every 3 weeks | - | - | 130mg/m^2^ IV on day 1 plus 5- fluorouracil continuous infusion days 1–4) every 3 weeks
Number of evidence citations | - | - | 2 | - | - | 1
Range of years of citations | - | - | 1990–2002 | - | - | 2002
Sources of evidence (abstracts/published 0rticles) | - | - | Articles | - | - | Article
Number of abstracts cited [years] | - | - | 0 | - | - | 0
Number of published articles cited [years] | - | - | 2 (1990–2002) | - | - | 1 [2002]
Date of last update | 1/10/2006 | 09/22/2005 | NR | NR | 12/05/05 [12/05/2005]^*^ | 7/13/2005

* Last update of clinical practice guideline.

Studies cited in compendia versus studies identified in EPC review. Only Clinical Pharmacology and DRUGDEX provided any references (Table 4b). The same reference was cited by both.34 This reference was also identified in the EPC review. DRUGDEX also cited a 1990 Phase I trial that was not identified by the EPC.35 A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 4c.

Table 4c Articles cited by compendia vs. articles identified by EPC – oxaliplatin for breast cancer

Reference | EPC | AHFS-DI | USP-DI | DRUGDEX | F & C | NCCN | Clin Pharm
Reviewed by compendia: | - | No | No | Yes | No | No | Yes
Phase II/III
Delaloge 2004^31^ | x
Phase II
Cottu 2005^33^ | x
Gebbia 2004^36^ | x
Pectasides 2003^37^ | x
Thuss-Patience 2003^38^ | x
Leonardi 2002^39^ | x
Zelek 2002^34^ | x | | | x | | | x
Garufi 2001^32^ | x
Phase I/II
(none)
Phase I
Caussanel, 1990^35^ | | | | x
Other
(none)

Recommendations and supporting evidence. DRUGDEX lists an off-label indication for oxaliplatin for breast cancer after prior taxane and anthracycline treatment based on inconclusive evidence for efficacy of strength “Category B” (based on data derived from RCTs that involved small numbers of patients or had significant methodological flaws). The recommendation was “Class III” (not recommended).

Clinical Pharmacology provides an off-label indication for oxaliplatin for advanced or metastatic breast cancer after progression despite taxane and anthracycline therapy. It recommended the use of oxaliplatin in combination with 5-FU at a dose of 130mg/m^2^ every 3 weeks.

Summary. Listings of oxaliplatin for breast cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Two of the six compendia (DRUGDEX, Clinical Pharmacology) discuss oxaliplatin for treatment of breast cancer.
- Specificity of clinical information: The two compendia described a similar role for oxaliplatin in advanced or metastatic breast cancer after failure of taxane and anthracycline treatment. The compendia cite the same Phase II study of combination treatment with 5-FU and provide identical dosing information. Both compendia cite data on response rate, for which observed improvements are quantified; Clinical Pharmacology also mentions time to progression and median survival, for which no quantitative data are presented.
- Evidence rating: Only DRUGDEX provides an explicit evidence rating for the off-label indication of oxaliplatin for breast cancer, describing the evidence as category B and inconclusive. Both DRUGDEX and Clinical Pharmacology cite at least one reference.
- Recommendation statements: Only DRUGDEX provided an explicit recommendation on the off-label use of oxaliplatin for breast cancer, listing it as “Not recommended.”
- Toxicity: Toxicities related to oxaliplatin are reported in all of the compendia, but none notes toxicities specifically in patients with breast cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include breast cancer as an off-label indication for oxaliplatin. It emphasizes well-designed, controlled, published studies, but does not cite the published Phase II/III study identified in the EPC review. The last update was 1/10/06, but the 2004 Phase II/III study is not cited.
- USP-DI specifies that it includes off-label indications, but it does not include breast cancer as an off-label indication for oxaliplatin. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff, but it does not cite the Phase II/III study identified in the EPC review. The last update was 9/22/05; the Phase II/III study was presented at ASCO in June 2005.
- DRUGDEX specifies that it includes off-label indications, and it does include breast cancer as an off-label indication for oxaliplatin. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites two studies, but fails to cite additional studies identified in the EPC review, including the single Phase II/III trial (2005). The date of the last update was not reported, but 2005 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it does not include breast cancer as an off-label indication for oxaliplatin. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite the four clinical trials identified in the EPC review that meet these criteria. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is not an off-label indication for oxaliplatin in breast cancer as per the guideline. The last update was 12/5/05, but 2005 data are not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes breast cancer as an off-label indication for oxaliplatin. It emphasizes prospective trials, but does not cite any of the eight prospective studies identified in the EPC review. The last update was 7/13/05, but the Phase II/III study presented at ASCO in June 2005 is not cited.

## Oxaliplatin (Eloxatin®) for Lung Cancer

As stated above, oxaliplatin is a third-generation platinum analog. Oxaliplatin is a non-cell cycle specific, alkylating chemotherapeutic drug that impairs DNA synthesis by forming platinum-DNA crosslinks that inhibit DNA replication and transcription. Its activity and toxicity profiles differ from both cisplatin and carboplatin, and thus it lacks cross-resistance with these compounds. Unlike cisplatin or carboplatin, oxaliplatin is not associated with significant renal or auditory toxicity, and hematological toxicity is usually mild. Oxaliplatin has a large spectrum of anticancer activity and has been used in combination with many other chemotherapy agents.

Oxaliplatin is FDA approved as a second-line therapy for the treatment of metastatic colorectal cancer; a first-line treatment for advanced colorectal cancer; and an adjuvant treatment for stage III colorectal cancer. It has also been evaluated for off-label use for lung cancer.

### Systematic Review by EPC

A total of 109 articles and abstracts were identified through the EPC literature search. Of these, 20 met the EPC inclusion criteria. Nineteen of the 20 were abstracted. One Phase II study of oxaliplatin by continuous infusion published in 1990 could not be obtained for abstraction.

Table 5a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 4) reports details from each of the 19 studies. The literature review identified 18 prospective clinical trials, of which 12 were Phase II studies, two were Phase I/II, and four were Phase I. A total of 666 subjects were involved.

Table 5a Study types and outcomes reported – oxaliplatin for lung cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 19 | 666 | 1998–2005 | 16 | 7 | - | 11 | 19
Phase III | - | - | - | - | - | - | - | -
Phase II | 12 (63%) | 546 (82%) | 1998–2005 | 12 | 7 | - | 7 | 12
Phase I/II | 2 (11%) | 62 (9%) | 2001–2 | 2 | - | - | 1 | 2
Other^a^ | 5 (26%) | 58 (9%) | 2001–3 | 2 | - | - | 3 | 5
No. of above published as abstracts | 4 (21%) | 232 (35%) | 2004–5 | 4 | 2 | - | 2 | 4

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Four Phase I studies and 1 case report.

Peer-reviewed Phase III trials. No Phase III studies were identified.

Peer-reviewed Phase II trials. A total of 12 Phase II studies were identified, of which two were randomized.40, 41 All studies evaluated oxaliplatin in the setting of advanced stage III or IV NSCLC; 11 of 12 included patients in the first-line setting. One study evaluated oxaliplatin as monotherapy, and all others included co-interventions. Co-interventions included gemcitabine (n = 7 studies), vinorelbine (n = 1), docetaxel (n = 1), pemetrexed (n = 1), and paclitaxel (n = 1). Oxaliplatin doses ranged from 65 to 130 mg/m^2^. All concluded that oxaliplatin has activity in this setting, except an ASCO abstract by Lippe.42 Generally response rates were felt to be similar to other platinum-containing doublets, with equal or better tolerability. Further investigation was recommended. The data from randomized and non-randomized studies were similar.

Peer-reviewed Phase I/II trials. Oxaliplatin was combined with vinorelbine and administered and had activity, verifying plans to go on to Phase II studies.

Peer-reviewed Phase I and other studies. The four small Phase I studies and one case report all suggested that the Phase II studies described above were feasible and warranted.

### Compendia Listings

Treatment indication and toxicities. Table 5b summarizes the compendia’s discussions about the off-label use of oxaliplatin for treatment of lung cancer. Only DRUGDEX lists this as an off-label indication. All compendia discussed toxicities, including severity and frequency of adverse effects, and which organs have been reported to be affected. None discussed oxaliplatin-related toxicities specifically among patients being treated for lung cancer.

Table 5b Summary of compendia listings – oxaliplatin for lung cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | No | Yes | No | No | No
Sub-category of indication (accepted or acceptance not established) | - | - | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | - | - | -
Stage of cancers | - | - | Stage IV | - | - | -
Method of treatment (first line or other) | - | - | Monotherapy | - | - | -
Routes of administration | - | - | NR | - | - | -
Uses of the agent (monotherapy or combination) | - | - | NR | - | - | -
Comparator discussed (placebo, standard treatment, other agents) | - | - | NR | - | - | -
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | - | Response | - | - | -
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | - | 130 mg/m2 IV as a 2 hr infusion every 21 days | - | - | -
Number of evidence citations | - | - | 1 (+1)^a^ | - | - | -
Range of years of citations | - | - | 1998–2002 | - | - | -
Sources of evidence (abstracts/published articles) | - | - | Article | - | - | -
Number of abstracts cited [years] | - | - | 0 | - | - | -
Number of published articles cited [years] | - | - | 2 (1998–2002) | - | - | -
Date of last update | 1/10/2006 | 09/22/2005 | NR | NR | 03/04/05 [11/22/2005]^*^ | 7/13/2005

* Last update of clinical practice guideline.

a One article cited; 1 additional article included in the reference list.

Studies cited in compendia versus studies identified in EPC review. Only DRUGDEX provided any references about oxaliplatin for lung cancer treatment (Table 5b). A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 5c.

Table 5c Articles cited by compendia vs. articles identified by EPC – oxaliplatin for lung cancer

Reference | EPC | AHFS-DI | USP-DI | DRUGDEX | F & C | NCCN | C P
Reviewed by compendia: | -
Phase III
(none)
Phase II
Bidoli 2005^40^ | x
Broad 2005^43^ | x
Cappuzzo 2005^44^ | x
Kouroussis 2005^45^ | x
Lippe 2005^42^ | x
Santos 2005^46^ | x
Scagliotti 2005^41^ | x
Buosi 2004^47^ | x
Winegarden 2004^48^ | x
Franciosi 2003^49^ | x
Monnet 2002^50^ | x | | | *
Monnet 1998^51^ | x | | | x
Phase I/II
Faivre 2002^52^ | x
Monnet 2001^53^ | x
Phase I
Bidoli 2004^54^ | x
Doroshow 2003^55^ | x
Kouroussis 2003^56^ | x
Kakolyris 2002^57^ | x
Other
Santini 2001^58^ | x

* Non-cited reference.

Recommendations and supporting evidence. Only DRUGDEX lists an off-label indication for oxaliplatin for lung cancer. It bases this recommendation on inconclusive evidence for efficacy of strength “Category B” (based on data derived from RCTs that involved small numbers of patients or had significant methodological flaws). The recommendation was “Class III” (Not recommended). None of the other compendia list an off-label indication for this agent-disease combination.

Summary. Listings of oxaliplatin for lung cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Only DRUGDEX discusses oxaliplatin for treatment of lung cancer.
- Specificity of clinical information: DRUGDEX lists the indication for stage IV (metastatic) NSCLC. It gives specific dosing information for monotherapy based on two cited studies. DRUGDEX describes specific data on response rate as reported in one referenced study.
- Evidence rating: DRUGDEX provides an explicit evidence rating for the off-label indication of oxaliplatin for lung cancer. It rates the evidence as inconclusive, placing the strength of evidence in its second tier. Two studies are cited.
- Recommendation statements: DRUGDEX uses the evidence rating of Class III or “Not recommended” for the off-label indication of oxaliplatin for NSCLC.
- Toxicity: Toxicities related to oxaliplatin are reported in all of the compendia, but none notes toxicities specifically in patients with NSCLC.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include lung cancer as an off-label indication for oxaliplatin. There is no published Phase III study of oxaliplatin in lung cancer; thus the compendium adheres to its stated methodology, which emphasizes well-designed, controlled, published studies.
- USP-DI specifies that it includes off-label indications, but it does not include lung cancer as an off-label indication for oxaliplatin. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. No Phase III or IV studies were identified in the EPC review. The last update was 9/22/05, but 2004 and earlier data are not cited.
- DRUGDEX specifies that it includes off-label indications, and it does include lung cancer as an off-label indication for oxaliplatin. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only one of the 19 studies identified in the EPC review. The single cited reference is consistent with the monotherapy indication listed; however, a second study included in the reference list but not cited describes combined treatment with vinorelbine. The date of the last update was not reported, but 2005 and earlier data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it does not include lung cancer as an off-label indication for oxaliplatin. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite the seven clinical trials identified in the EPC review that meet these criteria. The date of the last update is not stated, but 2005 and earlier data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is not an off-label indication for oxaliplatin in lung cancer as per the guideline. The last update was 3/4/05, but no prior data are cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it does not include lung cancer as an off-label indication for oxaliplatin. It emphasizes prospective trials, but does not cite any of the 12 prospective Phase II studies identified in the EPC review. The last update was 7/13/05; published studies available prior to that date are not cited.

## Irinotecan (Camptosar®) for Breast Cancer

Irinotecan is an intravenous chemotherapeutic agent. It is a derivative of camptothecin, a cytotoxic plant alkaloid isolated from the Chinese tree Camptotheca acuminata. Irinotecan is a potent anticancer drug with activity in a broad range of experimental tumor models. Irinotecan and its metabolite SN-38 work by inhibiting topoisomerase I, a cellular enzyme involved in maintaining the topographic structure of DNA during translation, transcription, and mitosis. By binding with the topoisomerase I-DNA complex, irinotecan or SN-38 prevents the single-strand DNA breaks usually created by this complex. This activity is not in itself cytotoxic, and ongoing DNA synthesis is required to cause lethal cellular damage. Irreversible DNA damage occurs when a DNA replication fork encounters the irinotecan or SN-38/topoisomerase I complexes resulting in double-strand DNA breaks.

Irinotecan is FDA approved for the treatment of metastatic colorectal cancer that has recurred or progressed after therapy with 5-FU and as part of a first-line treatment regimen containing 5-FU and leucovorin for metastatic colorectal cancer. It has also been evaluated for off-label use in breast cancer.

### Systematic Review by EPC

A total of 151 articles and abstracts were identified through the EPC literature search. Of these, 10 met the EPC inclusion criteria.

Table 6a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 5) reports details from each of the 10 studies. The literature review identified nine prospective clinical trials, of which five were Phase II and four were Phase I, involving a total of 324 subjects. An additional 20 subjects were included in a retrospective review identifying activity of this agent in this setting.

Table 6a Study types and outcomes reported – irinotecan for breast cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 10 | 344 | 2001-5 | 8 | 4 | - | 7 | 10
Phase III | - | - | - | - | - | - | - | -
Phase II | 5 (50%) | 293 (85%) | 2003-5 | 5 | 3 | - | 4 | 5
Phase I | 4^a^ (40%) | 31 (9%) | 2004-5 | 2 | - | - | 2 | 4
Other | 1 (10%) | 20 (6%) | 2001 | 1 | 1 | - | 1 | 1
No. of above published as abstracts | 5 (50%) | 106 (31%) | 2004-5 | 3 | - | - | 2 | 5

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Three studies of mixed advanced solid tumor populations.

Peer-reviewed Phase III trials. No Phase III studies were identified.

Peer-reviewed Phase II trials. Of the five Phase II trials, two were randomized – one published by Perez et al in full-text form59 and one presented by Vukelja et al. at ASCO in 2005.^60^ The Perez study evaluated irinotecan monotherapy at 100 mg/m^2^ vs 240 mg/m^2^ in patients with previously treated metastatic breast cancer. Activity was nearly equal between these two doses. The Vukelja study evaluated irinotecan monotherapy at 60 mg/m^2^ vs 30 mg/m^2^ in patients with previously treated advanced breast cancer. The higher dose was somewhat more efficacious.

The other three Phase II studies were non-randomized. Two were published in full-text form.61, 62 Doses ranged from 100 to 300 mg/m^2^, and co-interventions were docetaxel and gemcitabine. All studies were in patients with previously treated advanced breast cancer.

Peer-reviewed Phase I and other studies. The five other studies evaluated irinotecan with a variety of co-interventions and doses. Complete information was not always provided, and populations were not necessarily limited to breast cancer. These studies predominantly supported the progression to Phase II trials.

### Compendia Listings

Treatment indication and toxicities. Table 6b summarizes the compendia’s discussions of the off-label use of irinotecan for treatment of breast cancer. Only DRUGDEX explicitly stated whether there was an off-label indication for the drug in the setting of this cancer. DRUGDEX stated that the evidence was inconclusive and that the recommendation was “level IIb.” All other compendia, regardless of whether they discussed an off-label indication for breast cancer or not, discussed toxicities, including severity and frequency of adverse effects, and which organs have been reported to be affected. None discussed irinotecan-related toxicities specifically among patients being treated for breast cancer.

Table 6b Summary of compendia listings – irinotecan for breast cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | No | Yes (Irinotecan hydrochloride) | No | No | No
Sub-category of indication (accepted or acceptance not established) | - | - | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class IIb^*^ Strength of Evidence: Adult, Category C^**^ | - | - | -
Stage of cancers | - | - | Advanced | - | - | -
Method of treatment (first line or other) | - | - | Other | - | - | -
Routes of administration | - | - | NR | - | - | -
Uses of the agent (monotherapy or combination) | - | - | NR | - | - | -
Comparator discussed (placebo, standard treatment, other agents) | - | - | NR | - | - | -
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | - | Response rate | - | - | -
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: No By organ: Yes Frequency: No | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes/ By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | - | No | - | - | -
Number of evidence citations | - | - | 2 | - | - | -
Range of years of citations | - | - | 1994–1997 | - | - | -
Sources of evidence (abstracts/published articles) | - | - | Journal | - | - | -
Number of abstracts cited [years] | - | - | | - | - | -
Number of published articles cited [years] | - | - | 2 [1994–1997] | - | - | -
Date of last update | 1/10/2006 | 10/28/2004 | NR | NR | 12/05/2005 | 1/30/2006

* Recommended in some cases. The given test or treatment is not generally considered to be useful. It may be indicated in some, but not most, cases.

** Based on data derived from expert opinion or consensus, case reports or case series.

Studies cited in compendia versus studies identified in EPC review. Only DRUGDEX provided any references (Table 6b); two references were cited, published in 1994 and 1997. Neither reference met the EPC criteria for inclusion, as both were narrative reviews. Further, more recent updates were identified by the EPC search. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 6c.

Table 6c Articles cited by compendia vs. articles identified by EPC – irinotecan for breast cancer

Reference | EPC | AHFS-DI | USP-DI | DRUGDEX | F & C | NCCN | Clin Pharm
Reviewed by compendia: | - | No | No | Yes | No | No | No
Phase III
(none)
Phase II
Frasci 2005^62^ | x
Moulder 2005^63^ | x
Vukelja 2005^60^ | x
Perez 2004^59^ | x
Agelaki 2003^61^ | x
Phase I/II
(none)
Phase I
Gold 2005^64^ | x
Faivre 2004^65^ | x
Frasci 2004^66^ | x
Verscharaegen 2004^67^ | x
Other
Shigeoka 2001^68^ | x
Rothenberg, 1997^69^ | | | | x^*^
Burris, 1994^70^ | | | | x^*^

* Did not meet EPC inclusion criteria because narrative review.

Recommendations and supporting evidence. DRUGDEX states that there is inconclusive evidence for a clear recommendation of irinotecan for breast cancer, indicating a recommendation of level IIb, evidence category C. Its cited references were narrative reviews from 1994 and 1997, much earlier than the currently available Phase II data. DRUGDEX does not specify whether irinotecan should be used as monotherapy or in combination; advanced breast cancer is the specified setting.

Summary. Listings of irinotecan for breast cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Only DRUGDEX discusses irinotecan for treatment of breast cancer.
- Specificity of clinical information: DRUGDEX lists the indication for advanced breast cancer. It does not give specific dosing information, citing two review articles. DRUGDEX mentions response rate, but does not cite specific data.
- Evidence rating: DRUGDEX provides an explicit evidence rating for the off-label indication of irinotecan for breast cancer. It rates the evidence as inconclusive, placing the strength of evidence in its lowest tier, corresponding to data derived from expert opinion or consensus, case reports, or case series. Two references are cited, both review articles.
- Recommendation statements: DRUGDEX uses the evidence rating of Class IIb, or “Recommended in some cases … not generally considered to be useful … may be indicated in some, but not most cases.”
- Toxicity: Toxicities related to irinotecan are reported in all of the compendia, but none notes toxicities specifically in patients with breast cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include breast cancer as an off-label indication for irinotecan. There is no published Phase III study of irinotecan in breast cancer; thus the compendium adheres to its stated methodology, which emphasizes well-designed, controlled, published studies.
- USP-DI specifies that it includes off-label indications, but it does not include breast cancer as an off-label indication for irinotecan. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff; no Phase III or IV studies were identified in the EPC review. The last update was 10/28/04; no relevant data would have been identified during later searches.
- DRUGDEX specifies that it includes off-label indications, and it does include breast cancer as an off-label indication for irinotecan. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only two old narrative reviews and does not cite any data after 1997. The date of the last update was not reported, but 2005 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it does not include breast cancer as an off-label indication for irinotecan. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite the four clinical trials identified in the EPC review that meet these criteria. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is not an off-label indication for irinotecan in breast cancer as per the guideline. The last update was 12/5/05, but 2005 data are not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it does not include breast cancer as an off-label indication for irinotecan. It emphasizes prospective trials, but does not cite the nine prospective studies identified in the EPC review. The last update was 1/30/06, but 2005 data are not cited.

## Docetaxel (Taxotere®) for Esophageal Cancer

Docetaxel is a semisynthetic antimicrotubule chemotherapy agent. It was isolated in 1986 as a result of the National Cancer Institute (NCI) screening program for natural cytotoxic products. Docetaxel promotes the assembly of microtubules and stabilizes their formation by inhibiting depolymerization. These stable microtubules are non-functional, preventing cell division. Docetaxel is similar to paclitaxel in structure, mechanism of action, and spectrum of antitumor activity. Non-hematologic toxicities differ between docetaxel and paclitaxel; fluid retention and skin lesions are more severe with docetaxel. The efficacy for docetaxel has been explored with myriad solid tumors including breast, colorectal, head and neck, gastrointestinal (GI), lung, and ovarian cancers. It is effective alone or in combination with other agents.

Docetaxel is FDA approved (1) for the treatment of refractory, locally advanced or metastatic breast cancer; (2) as an adjuvant agent (in combination with doxorubicin and cyclophosphamide) in breast cancer patients with lymph node positive disease; (3) for the treatment of advanced or metastatic NSCLC after progression despite platinum-containing chemotherapy; and (4) for the treatment of metastatic, hormone-refractory prostate cancer. It has also been evaluated for off-label use in esophageal cancer.

### Systematic Review by EPC

A total of 132 articles and abstracts were identified through the EPC literature search. Of these, 23 met the EPC inclusion criteria.

Table 7a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 6) reports details from each of the 23 studies. The literature review identified 21 prospective clinical trials, of which 13 were Phase II, six Phase I/II, and two Phase I. A total of 721 subjects were involved in the prospective clinical trials.

Table 7a Study types and outcomes reported – docetaxel for esophageal cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 23 | 1026 | 1996–2005 | 16 | 11 | - | 19 | 20
PHASE II | 13 (57%) | 521 (51%) | 1996–2005 | 11 | 9 | - | 11 | 12
Phase I/II | 6 (26%) | 163 (16%) | 2004–5 | 4 | - | - | 6 | 6
Phase I | 2 (9%) | 37 (4%) | 1998–2004 | - | - | - | 1 | 1
Other | 2 (9%) | 305 (30%) | 2000–3 | 1 | 2 | - | 1 | 1

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

Peer-reviewed Phase II trials. There were 13 peer-reviewed Phase II trials. Only one was randomized. This was a study of docetaxel plus cisplatin vs the same regimen plus 5-FU. Doses of docetaxel used in the Phase II studies ranged from 25 to 100 mg/m^2^, except in the neoadjuvant setting (two studies) where doses were 10 to 35 mg/m^2^. Four studies evaluated docetaxel as monotherapy. Co-interventions included radiotherapy, vinorelbine, cisplatin, 5-FU, and irinotecan. Patient populations included all stages of disease and treatment settings (first line, post-first line, heavily pretreated) although more studies included patients with advanced disease. All trials included a statement supporting the need for further study of docetaxel in esophageal cancer, although some also included a statement recommending close attention to the toxicities of some of the various docetaxel combinations.

One important limitation of this literature was that the studies often included patients with gastric or gastroesophageal cancer. Often there was not a clear distinction between esophageal, gastric, and gastroesophageal cancer, consistent with the occasional clinical difficulties with distinguishing these. At least five of the 13 Phase II trials included patients in all three groups.

### Compendia Listings

Treatment indication and toxicities. Table 7b summarizes the compendia’s discussions of the off-label use of docetaxel for treatment of esophageal cancer. Four of the six compendia had an off-label listing of docetaxel in esophageal cancer. USP-DI characterized this as “Accepted,” whereas DRUGDEX, Facts & Comparisons, and NCCN were less emphatic. All the compendia, regardless of whether they discussed an off-label indication for esophageal cancer or not, discussed toxicities, including severity and frequency of adverse effects, and which organs have been reported to be affected. None discussed docetaxel-related toxicities specifically among patients being treated for esophageal cancer.

Table 7b Summary of compendia listings – docetaxel for esophageal cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | Yes | Yes | Yes | Yes | No
Sub-category of indication (accepted or acceptance not established) | - | Accepted | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | Unlabeled use | 2A | -
Stage of cancers | - | Advanced and/or metastatic carcinomas, incl. adenocarcinomas and squamous cell carcinomas | Incurable adenocarcinoma of the esophagus | NR | Recurrent or metastatic disease | -
Method of treatment (first line or other) | - | NR | Other | NR | Other | -
Routes of administration | - | IV | IV | IV | IV | -
Uses of the agent (monotherapy or combination) | - | After failure of platinum-based therapy Monotherapy or combination (gemcitabine, cisplatin, 5-FU, leucovorin) and radiation therapy | Mono | NR | Combination | -
Comparator discussed (placebo, standard treatment, other agents) | - | NR | NR | NR | NR | -
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | NR | Response rate, median survival time, 1-year survival rate, time to disease progression | NR | Response rate, morbidity | -
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: No By organ: No Frequency: No | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: No Indication-specific: No Severity: No By organ: No Frequency: No | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | Combo: 60 to 85 mg/m2, by 1-hr infusion, every 21 to 28 d Mono: 100 mg/m2, by 1-hr infusion, every 21 d | 75 mg/m^2^ every 3 weeks for a maximum number of 8 cycles | NR | NR | -
Number of evidence citations | - | 17 | 1 (+4) | 3 | 3 | -
Range of years of citations | - | 1994–2000 | 2002 | 2002–2005 | 2002–2004 | -
Sources of evidence (abstracts/published articles) | - | Journal; Abstracts; Other | Journal; Abstracts | Package insert, reference book, textbook | Journals, abstracts | -
Number of abstracts cited [years] | - | 8 [2000] | 4 [1996–2000] | 0 | 2 [2002–2004] | -
Number of published articles cited [years] | - | 8 [1994–2000] | 1 [2002] | 0 | 1 [2004] | -
Date of last update | 1/10/2006 | 11/28/2005 | NR | NR | 1/13/05 (2/7/06] | 11/15/2005

Studies cited in compendia versus studies identified in EPC review. USP-DI, DRUGDEX, Facts & Comparisons, and NCCN all provided references. These references were not necessarily specific to esophageal cancer, nor were they all peer-reviewed articles. USP-DI predominantly cited references to studies of gastric cancer patients to support the indication “gastric and esophageal cancer.” Facts & Comparisons included three items, none of which was a peer-reviewed article. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 7c.

Table 7c Articles cited by compendia vs. articles identified by EPC – docetaxel for esophageal or gastric cancer

Reference | EPC | AHFS | USP-DI | DRUGDEX | F & C | NCCN | Clin Pharm | Notes
Reviewed by compendia: | - | No | Yes | Yes | Yes | Yes | No | -
Phase III
(none)
Phase II
Ajani, 2005^71^ | x
Burtness, 2005^72^ | x
Kajiyama, 2005^73^ | x
Lorenzen, 2005^74^ | x
Lorenzen, 2005^75^ | x
Muro, 2004^76^ | x | | | | | X
Posey, 2004^77^ | x
Airoldi, 2003^78^ | x
Govindan, 2003^79^ | x
Lordick, 2003^80^ | x
Schull, 2003^81^ | x
Font, 2002^82^ | | | | | | x^***^
Heath, 2002^83^ | x | | | x
Jatoi, 2002^84^ | x
Ridwelski 2001^85^ | | | | x^*^
Ajani, 2000^86^ | | | x^**^ | @ | | | | Abstract
Eniu, 2000^87^ | | | x^*^ | @^*^ | | | | Abstract
Giuliani, 2000^88^ | | | x^*^ | @^*^ | | | | Abstract
Mauer, 2000^89^ | | | x^***^ | @
Mavroudis, 2000^90^ | | | x^*^ | @^*^
Thuss-Patience, 2000^91^ | | | x^*^
Einzig, 1996^92^ | x | | x | @
Sulkes, 1994^93^ | | | x^*^
Phase I/II
Pasini, 2005^94^ | x
Tsai, 2005^95^ | x
Yuki, 2005^96^ | x
Bubis, 2004^97^ | x
Enzinger, 2004^98^ | x | | | | | X
Roth, 2000^99^ | | | x^***^
Roth, 2000^100^ | x | | x^**^
Mauer, 1998^101^ | x | | x
Phase I
Syed, 2005^102^ | x
Poole, 2000^103^ | | | x^***^
Puccio, 2000^104^ | | | x^***^ | @ | | | | Abstract
Ryan, 2000^105^ | | | x$
Vokes, 1998^106^ | x | | x
Other
Esmaeli, 2003^107^ | x
Jani, 2000^108^ | x
Verweij, 1995^109^ | | | x^#^
Anonymous, 2001^110^ | | | x^#^
Package insert111 | | | | | x^#^,%
Textbook112 | | | | | x^#^
Database113 | | | | | x^#^

* Gastric cancer, not esophageal.

** Full-text version of article published and cited by EPC.

*** Abstract from prior to 2004 (did not meet EPC criteria).

$ Unclear if any esophageal cancer patients are included.

# Does not meet EPC inclusion criteria because it is a review article or other non-peer reviewed item.

@ Non-cited reference.

% Additional data from editor identified that there was an error in citation; more specific information provided indicating the textbook was the intended citation.

Recommendations and supporting evidence. USP-DI has 17 citations, only three of which met the EPC criteria. Five of these were for gastric cancer specifically and not esophageal cancer. The one DRUGDEX citation was a Phase II trial also identified by the EPC search; additional relevant references were listed in DRUGDEX but were not cited, including four relevant to esophageal cancer and four relevant to gastric cancer. Facts & Comparisons listed three citations, but none of these was peer-reviewed. Of the three NCCN citations, two were cited by the EPC and one was an abstract presented before 2004 and not published in full text since. None of the compendia cited the only randomized study identified by this review.

Summary. Listings of docetaxel for esophageal cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Four of the six compendia (USP-DI, DRUGDEX, Facts & Comparisons, and NCCN) discuss docetaxel for treatment of esophageal cancer.
- Specificity of clinical information: To describe the cancer indication, those compendia that discuss the off-label use of docetaxel in esophageal cancer describe various subgroups of patients. USP-DI uses “advanced and/or metastatic including adenocarcinomas and squamous cell carcinomas.” DRUGDEX indications are limited to adenocarcinomas. Facts & Comparisons and NCCN are not specific regarding the cell type, although NCCN notes that nearly all evidence is from trials of patients with squamous cell carcinoma. While USP-DI includes mono- or combination-treatment, DRUGDEX lists only monotherapy, and NCCN lists only combination therapy, while Facts & Comparisons does not specify. DRUGDEX and NCCN describe the outcome of response rate, reporting some quantitative data from one study.
- Evidence rating: Only DRUGDEX and NCCN provide explicit evidence ratings for the off-label indication of docetaxel for esophageal cancer. DRUGDEX rates the evidence as inconclusive and in its second tier (B), while NCCN rates the evidence in its second tier (“lower” quality), but with uniform consensus. USP-DI includes an extensive list of references, but these are reported only as lists of the available evidence and are not explicitly rated. DRUGDEX and NCCN cite five and three studies, respectively, while Facts & Comparisons cites a textbook and other non-peer reviewed references.
- Recommendation statements: Three of the four compendia listing this off-label indication grade the recommendation. DRUGDEX rates it as class III (“Not recommended”) based on inconclusive evidence, while NCCN uses evidence rating 2A, indicating uniform consensus (in the corresponding NCCN guideline, which was updated in 12/20/05, the evidence for this indication is rated as category 3, indicating major disagreement that the indication is appropriate). USP-DI lists the off-label use under the “Accepted” category. Facts & Comparisons does not grade the off-label use of docetaxel in esophageal cancer.
- Toxicity: Toxicities related to docetaxel are reported in most of the compendia, but none notes toxicities specifically in patients with esophageal cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include esophageal cancer as an off-label indication for docetaxel. There is no published Phase III study of docetaxel in esophageal cancer; thus the compendium adheres to its stated methodology, which emphasizes well-designed, controlled, published studies.
- USP-DI specifies that it includes off-label indications, and it does include esophageal cancer as an off-label indication for docetaxel. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. Seventeen citations are listed, of which eight are classified as Phase II; the rest are of lower phases. Only two of the cited Phase II studies met the EPC inclusion criteria. The last update was 1/28/05; the majority of citations identified by the EPC are prior to that date.
- DRUGDEX specifies that it includes off-label indications, and it does include esophageal cancer as an off-label indication for docetaxel. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only one of the 23 studies identified in the EPC review (eight additional studies are listed in the references, but not cited). The date of the last update was not reported, but data published since 2002 are neither cited nor listed in references.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes esophageal cancer as an off-label indication for docetaxel. It emphasizes Phase II, III, and IV studies with over 30 subjects, but cites only non-peer-reviewed publications. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is an off-label indication for docetaxel in esophageal cancer as per the guideline. The last update was 1/13/05, and 2004 data are cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it does not include esophageal cancer as an off-label indication for docetaxel. It emphasizes prospective trials, but does not cite the prospective studies identified in the EPC review. The last update was 11/15/05, but earlier 2005 data are not cited.

## Docetaxel (Taxotere®) for Gastric Cancer

As stated above, docetaxel is a semisynthetic antimicrotubule chemotherapy agent. It was isolated in 1986 as a result of the NCI screening program for natural cytotoxic products. Docetaxel promotes the assembly of microtubules and stabilizes their formation by inhibiting depolymerization. These stable microtubules are non-functional, preventing cell division. Docetaxel is similar to paclitaxel in structure, mechanism of action, and spectrum of antitumor activity. Non-hematologic toxicities differ between docetaxel and paclitaxel; fluid retention and skin lesions are more severe with docetaxel. The efficacy for docetaxel has been explored with myriad solid tumors including breast, colorectal, head and neck, GI, lung, and ovarian cancers. It is effective alone or in combination with other agents.

Docetaxel is FDA approved (1) for the treatment of refractory, locally advanced or metastatic breast cancer; (2) as an adjuvant agent (in combination with doxorubicin and cyclophosphamide) in breast cancer patients with lymph node positive disease; (3) for the treatment of advanced or metastatic NSCLC after progression despite platinum-containing chemotherapy; and (4) for the treatment of metastatic, hormone-refractory prostate cancer. It has also been evaluated for off-label use in gastric cancer.

### Systematic Review by EPC

A total of 132 articles and abstracts were identified through the EPC literature search. Of these, 72 appeared to meet the EPC inclusion criteria.

Appendix B (Evidence Table 7) reports details from each of the 72 studies. Among these 72 articles or abstracts, there were several that presented the same data. We found it impossible to eliminate the duplicate data among the lower phase studies (Phase I and Phase II); therefore, we have limited this analysis to Phase III studies only, for which duplicate publication was not a problem. There were three Phase III studies.114–116

Peer-reviewed Phase III trials. The three Phase III studies evaluated docetaxel for gastric cancer, all in the advanced cancer setting. In the study by Fahlke,115 docetaxel was combined with cisplatin and compared with 5-FU, leucovorin, and cisplatin. Preliminary safety results are available only for the first 162 of a planned 216 subjects. In a study by Elsaid,114 docetaxel was combined with carboplatin and compared to epirubicin, cisplatin, and 5-FU. The docetaxel combination was superior in terms of response and survival. In the study by Moiseyenko,116 docetaxel was combined with cisplatin and 5-FU and compared to cisplatin and 5-FU alone. Response rates were better and survival was longer when docetaxel was added.

### Compendia Listings

Treatment indication and toxicities. Table 8 summarizes the compendia’s discussions of the off-label use of docetaxel for treatment of gastric cancer. Five of the six compendia had an off-label listing of docetaxel in gastric cancer. USP-DI characterized this as “Accepted,” whereas DRUGDEX, Facts & Comparisons, NCCN, and Clinical Pharmacology were less emphatic. All the compendia, regardless of whether they discussed an off-label indication for gastric cancer or not, discussed toxicities, including severity and frequency of adverse effects, and which organs have been reported to be affected. DRUGDEX and NCCN discussed docetaxel-related toxicities specifically among patients being treated for gastric cancer.

Table 8 Summary of compendia listings – docetaxel for gastric cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | Yes | Yes | Yes | Yes | Yes
Sub-category of indication (accepted or acceptance not established) | | Accepted | Efficacy: Adult, Evidence favors efficacy Recommendation: Adult, Class IIb Strength of Evidence: Adult, Category B | Unlabeled indication | 2A | Advanced
Stage of cancers | | Advanced and/or metastatic, including adenocarcinomas and squamous cell carcinomas | Metastatic | NR | Unresectable locoregional disease Following a grossly margin positive resection (R2) in medically fit patients with locoregional disease (M0) Recurrent or metastatic disease | Advanced gastric cancer
Method of treatment (first line or other) | | Other | NR | NR | First-line and other | First line and other
Routes of administration | | IV | IV | IV | IV | IV
Uses of the agent (monotherapy or combination) | | Monotherapy or in combination (gemcitabine, cisplatin, 5–FU, leucovorin) and radiation therapy | Combination (cisplatin) | NR | Combination | Monotherapy
Comparator discussed | | NR | None | NR | Yes | NR
Outcomes mentioned for the off-label use (survival, tumor response, other) | | NR | Survival Response Time to progression | NR | NR | Partial response, stable disease
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: Yes Severity: Yes By organ: Ys Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: No Indication-specific: No Severity: No By organ: No Frequency: No
Dose indicated for the off-label use | | Combo: 60 to 85 mg/m2, by 1-hr infusion, every 21 to 28 days Mono: 100 mg/m^2^, by 1-hour infusion, every 21 days | 75 mg/ m^2^ and cisplatin 75 mg/m^2^ every 3 weeks for 6 cycles | NR | Many regimens may be considered in the first-line setting No established second-line | Dosage regimen not established
Number of evidence citations | | 17 | 1 (+ 8)^a^ | 3 | 4 | 2
Range of years of citations | | 1994–2000 | 2001 | 2002–2005 | 1994–2000 | 2003
Sources of evidence (abstracts/published articles) | | Journal; Abstracts; Other | Journals | Package insert, text books | Journals | Published articles
Number of abstracts cited [years] | | 8 [2000] | 4 [2000] | 0 | 0 | 0
Number of published articles cited [years] | | 8 [1994–2000] | 5 [1996–2001] | 0 | 4 [1994–2000] | 2 [2003]
Date of last update | 1/10/2006 | 11/28/2005 | NR | NR | 1/12/05 (1/11/06) | 11/15/2005

a 1 article cited; 8 additional articles included in the reference list (4 esophageal cancer and 4 gastric cancer).

Studies cited in compendia versus studies identified in EPC review. Each of the five compendia listing a gastric cancer indication provided some references. These references were not necessarily specific to the gastric cancer indication, nor were all peer-reviewed articles. As noted above, we limited our analysis to the three Phase III trials, all of which were abstracts published in 2005.

Recommendations and supporting evidence. None of the compendia cited any of the three Phase III studies published in 2005, although one (Facts & Comparisons) included a 2005 citation. As noted above, we limited our analysis for this topic to the three Phase III trials.

Summary. Listings of docetaxel for gastric cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Five of the six compendia (all except AHFS-DI) discuss docetaxel for treatment of gastric cancer.
- Specificity of clinical information: To describe the cancer indication, those compendia that discuss the off-label use of docetaxel in gastric cancer use different ad hoc nomenclatures (e.g., USP-DI uses “advanced and/or metastatic,” while DRUGDEX uses “metastatic” and Clinical Pharmacology uses “advanced”; NCCN describes the cancer indication in more specific terms that conform to standardized staging classification). Three compendia describe combination treatment (USP-DI, DRUGDEX, NCCN), while two list monotherapy (USP-DI, Clinical Pharmacology), including information about dosages; Facts & Comparisons does not describe use as mono- or combination-therapy. Only two compendia describe outcomes affected by treatment: DRUGDEX lists survival, response rate, and time to progression, while Clinical Pharmacology describes partial response and stable disease. No specific quantitative estimates of the magnitude of benefit are reported.
- Evidence rating: Only two compendia (DRUGDEX and NCCN) provide explicit evidence ratings for the off-label indication of docetaxel for gastric cancer. DRUGDEX describes the evidence as “favors efficacy” and rates it in the second tier. NCCN also places the evidence in its second tier. USP-DI includes the most extensive list of references with 17 citations, but these are reported only as lists of the available evidence. The other compendia cite between two and nine references.
- Recommendation statements: NCCN grades the off-label indication as 2A, indicating lower level evidence but uniform consensus about the appropriateness of the indication (in the corresponding NCCN guideline, which was updated in 1/11/06, the evidence for this indication is rated as category 3, indicating major disagreement that the indication is appropriate). DRUGDEX grades its recommendation as “Recommended in some cases” (Class IIb). USP-DI lists the off-label use under the “Accepted” category without further qualification. Facts & Comparisons and Clinical Pharmacology make no further mention on the off-label use of docetaxel in gastric cancer.
- Toxicity: Toxicities related to docetaxel are reported in most of the compendia, but only DRUGDEX and NCCN note toxicities specifically in patients with gastric cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include gastric cancer as an off-label indication for docetaxel. It emphasizes well-designed, controlled, published studies and – consistent with its policy not to include abstracts – does not cite any of the three Phase III studies identified in the EPC review.
- USP-DI specifies that it includes off-label indications, and it does include gastric cancer as an off-label indication for docetaxel. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. Seventeen citations are listed, of which eight are classified as Phase II; the rest are of lower phases. The last update was 1/28/05, which was prior to the publication of the three Phase III studies identified by the EPC.
- DRUGDEX specifies that it includes off-label indications, and it does include gastric cancer as an off-label indication for docetaxel. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only one of the studies identified in the EPC review (eight additional studies are included in the references but not cited). The date of the last update was not reported, but data published since 2002 are neither cited nor listed in references.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes gastric cancer as an off-label indication for docetaxel. It emphasizes Phase II, III, and IV studies with over 30 subjects, but cites only non-peer-reviewed publications. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is an off-label indication for docetaxel in gastric cancer as per the guideline. The last update was 1/11/06, but data published after 2000 are not cited, including data from the three Phase III studies published in 2005.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes gastric cancer as an off-label indication for docetaxel. It emphasizes prospective trials, but does not cite the Phase III studies identified in the EPC review. The date of the last update was 11/15/05, but no data after 2003 are cited.

## Docetaxel (Taxotere®) for Ovarian Cancer

As stated above, docetaxel is a semisynthetic antimicrotubule chemotherapy agent. It was isolated in 1986 as a result of the NCI screening program for natural cytotoxic products. Docetaxel promotes the assembly of microtubules and stabilizes their formation by inhibiting depolymerization. These stable microtubules are non-functional, preventing cell division. Docetaxel is similar to paclitaxel in structure, mechanism of action, and spectrum of antitumor activity. Non-hematologic toxicities differ between docetaxel and paclitaxel; fluid retention and skin lesions are more severe with docetaxel. The efficacy for docetaxel has been explored with myriad solid tumors including breast, colorectal, head and neck, GI, lung, and ovarian cancers. It is effective alone or in combination with other agents.

Docetaxel is FDA approved (1) for the treatment of refractory, locally advanced or metastatic breast cancer; (2) as an adjuvant agent (in combination with doxorubicin and cyclophosphamide) in breast cancer patients with lymph node positive disease; (3) for the treatment of advanced or metastatic NSCLC after progression despite platinum-containing chemotherapy; and (4) for the treatment of metastatic, hormone-refractory prostate cancer. It has also been evaluated for off-label use in ovarian cancer.

### Systematic Review by EPC

A total of 143 articles and abstracts were identified through the EPC literature search. For the ovarian cancer topic, we abbreviated our inquiry, because the large number of citations was expected to exceed our capacity. Therefore, we eliminated several steps in our methodology and in our reporting for this topic: (1) we did not search abstracts presented at the 2004 or 2005 American Society of Clinical Oncology (ASCO) annual meeting; (2) we did not abstract each study into evidence tables; and (3) we do not summarize the results of individual trials by research phase below.

Of the 143 citations identified, 57 appeared to meet the EPC inclusion criteria. We evaluated the abstracts of these citations to classify them by study design. Of the 53 with abstracts, there were 28 prospective clinical trials, of which one was Phase III, 16 Phase II, one Phase I/II, and 10 Phase I.

### Compendia Listings

Treatment indication and toxicities. Table 9a summarizes the compendia’s discussions of the off-label use of docetaxel for treatment of ovarian cancer. Five of the six compendia had an off-label listing of docetaxel in ovarian cancer. USP-DI characterized this as “Accepted”; Facts & Comparisons and Clinical Pharmacology mentioned no qualifiers, while DRUGDEX and NCCN both qualified the indication. None discussed docetaxel-related toxicities specifically among patients being treated for ovarian cancer.

Table 9a Summary of compendia listings – docetaxel for ovarian cancer

| AHFS-DI | USP-DI | DRUGDEX | Facts & Comparisons | NCCN | Clinical Pharmacology
Off-label indication explicitly stated | No | Yes | Yes | Yes | Yes | Yes
Sub-category of indication (accepted or acceptance not established) | | Accepted | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class IIb Strength of Evidence: Adult, Category B | Unlabeled use | 2B (2A for recurrence) | NR
Stage of cancers | | Ovarian carcinoma after prior platinum-based therapy has failed | Ovarian cancer, advanced, previously treated | NR | Bulky stage III/IV disease Incompletely staged (stage IA-IB, grade 2–3, stage IC and stage II to IV) patients with no suspected residual or resectable disease Pathologic stage IA-IB (grades 2–3) and stage IC (all grades) Stage II to IV disease with interval debulking Clinical relapse or recurrence | Advanced: previously treated patients
Method of treatment (first line or other) | | Other | Other | NR | Primary/adjuvant + palliation | First line and other
Routes of administration | | IV | IV | IV | IV | IV
Uses of the agent (monotherapy or combination) | | Alone or in combination | Combination | NR | Alone or in combination | Monotherapy
Comparator discussed (placebo, standard treatment, other agents) | | NR | NR | NR | Yes | NR
Outcomes mentioned for the off-label use (survival, tumor response, other) | | NR | Partial responses, progression-free survival, survival | NR | NR | Response rates, median progression-free survival, and overall survival
Toxicity reporting | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Indication-specific: No Severity: No By organ: No Frequency: No | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: No Indication-specific: No Severity: No By organ: No Frequency: No | Overall: Yes Indication-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | | 100 mg/m^2^ every 3 wks over 1-hr | 100 mg/m^2^ IV every 3 weeks | NR | 60–75 mg/m^2^ over 1 hour and carboplatin AUC 5–6 every 3 weeks | 100 mg/m^2^ IV over 1 hour every 3 weeks
Number of evidence citations | | 5 | 9 (+ 4)^a^ | 3 | 3 | 1
Range of years of citations | | 1994–1997 | 1992–1998 | 2002–2005 | 2004 | 1997
Sources of evidence (abstracts/published articles) | | Journals; Abstracts Other | Journals | Package insert, textbook, reference book | Journal | Article
Number of abstracts cited [years] | | 2 [1994] | 1 [1993] | 0 | 0 | 0
Number of published articles cited [years] | | 2 [1994–1995] | 8 [1992–1998] | 0 [2002–2005] | 3 [2003–2004] | 1 [1997]
Date of last update | 1/10/20006 | 11/28/2005 | NR | NR | 1/13/2006 (1/3/06) | 11/15/2005

a Nine articles cited; four additional articles included in the reference list.

Studies cited in compendia versus studies identified in EPC review. Each of the compendia listing an indication of docetaxel for ovarian cancer provided references. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 9b.

Table 9b Articles cited by compendia vs. articles identified by EPC – docetaxel for ovarian cancer

Reference | EPC | AHFS- DI | USP-DI | DRUGDEX | F & C | NCCN | Clin Pharm | Notes
Reviewed by compendia: | - | No | Yes | Yes | Yes | Yes | Yes | -
Phase III
Vasey, 2004^117^ | x | | | | | x
Markman, 2003^118^ | | | | | | x | | Paclitaxel
Parmar, 2003^119^ | | | | | | x | | Paclitaxel
Phase II
Polyzos, 2005^120^ | x
Berkenblit, 2004^121^ | x
Dieras, 2004^122^ | x
Markman, 2004^123^ | x
Aravantinos 2003^124^ | x
Markman, 2003^125^ | x
Rose, 2003^126^ | x
Vorobiof, 2003^127^ | x
Laport, 2001^128^ | x | | | @
Markman, 2001^129^ | x
Katsumata, 2000^130^ | x
Vasey, 1999^131^ | x
Kavanagh, 1996^132^ | x
Kaye, 1995^133^ | x
Piccart, 1995^134^ | x | | x | x
Aapro, 1994^135^ | | | x^*^ | | | | | Abstract
Fossella, 1994^136^ | | | | x
Francis, 1994^137^ | x | | x | x
McGuire, 1989^138^ | | | | @
Phase I/II
Pfisterer, 2004^139^ | x
Phase I
Komiyama, 2005^140^ | x
Berkenblit, 2003^141^ | x
de Bree/Romanos 2003^142^ | x
de Bree/Rosing 2003^143^ | x
Morgan, 2003^144^ | x
Oishi, 2003^145^ | x
Terauchi, 2003^146^ | x
O’Neill, 2002^147^ | x
Vasey, 2001^148^ | x
Soulie, 1997^149^ | x
Tomiak, 1994^150^ | | | | x
Huizing, 1993^151^ | | | | @
Pazdur, 1992^152^ | | | | x
Other
Brown, 2005^153^ | x
Kuribayashi, 2005^154^ | x
Martino, 2005^155^ | x
Montero, 2005^156^ | x
Watanabe, 2005^157^ | x
Brown, 2004^158^ | x
Hsu, 2004^159^ | x
Esmaeli, 2003^107^ | x
Finsterer, 2003^160^ | x
Reviewed by compendia: | - | | Yes | Yes | Yes | Yes | Yes | -
Komiyama, 2003^161^ | x
McNally, 2003^162^ | x
Niwa, 2003^163^ | x
Aoki, 2002^164^ | x
Hirai, 2002^165^ | x
Jeyakumar, 2001^166^ | x
Kouroussis, 2000^167^ | x
Lister-Sharp, 2000^168^ | x
Verschraegen, 2000^169^ | x
Benjapibal, 1998^170^ | x | | | x
Eisenhauer, 1998^171^ | x
Balat, 1997^172^ | x
Behar, 1997^173^ | x
Kaye, 1997^174^ | x | | | | | | x | Review
Eisenhauer, 1996^175^ | x
Sweeten, 1995^176^ | x
Kavanagh, 1994^177^ | | | x^*^ | @ | | | | Abstract
Package insert111 | | | | | x^#^,%
Textbook112 | | | | | x^#^
Database113 | | | | | x^#^
Anonymous, 1993^178^ | | | | x^*^ | | | | Abstract
Pazdur, 1993^179^ | | | | x | | | | Review
Rowinsky, 1992^180^ | | | | x | | | | Review
No. of Abstracts | 0 | | 2 | 1
Abstract Years

* Abstract from prior to 2004 (did not meet EPC inclusion criteria).

# Does not meet EPC inclusion criteria because it is a review article or other non-peer reviewed item.

@ Non-cited reference.

% Additional data from editor identified that there was an error in citation; more specific information provided indicating the textbook was the intended citation.

Recommendations and supporting evidence. USP-DI has five citations, only three of which met the EPC criteria. Three were Phase II studies, and one was a document described as “Panel consensus on monograph draft of 5/22/97.” One abstract was too old to be obtained on the ASCO web site, so we could not assess its design.

DRUGDEX cited nine citations including three Phase II studies, two Phase I studies, one abstract we could not obtain, and two reviews. Facts & Comparisons listed three citations, but none of these was peer-reviewed (textbook, reference database, and package insert). Of the three NCCN citations, all were Phase III trials; two of the trials were of paclitaxel, while one was a study of docetaxel. These references were cited in the NCCN guideline in a statement supporting the use of “taxanes” (docetaxel and paclitaxel). Clinical Pharmacology cited a review of Phase II trials.174

Summary. Listings of docetaxel for ovarian cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Five of the six compendia (all except AHFS-DI) discuss docetaxel for treatment of ovarian cancer.
- Specificity of clinical information: To describe the cancer indication, those compendia that discuss the off-label use of docetaxel in ovarian cancer use different ad hoc nomenclatures (e.g., USP-DI, DRUGDEX, and Clinical Pharmacology describe the indication as advanced ovarian cancer [or carcinoma]; NCCN provides more specific indications that conform to a standardized staging classification). Facts & Comparisons does not describe the stage of disease for which treatment is indicated. Combination treatment is described in USP-DI, DRUGDEX, and NCCN, while USP-DI and Clinical Pharmacology list monotherapy; however, NCCN is the only compendium to list specific combination agents and dosages. DRUGDEX and Clinical Pharmacology describe outcomes of response rates, progression-free survival, and overall survival, but none quantify the effects of treatment.
- Evidence rating: Only two compendia (DRUGDEX and NCCN) provide explicit evidence ratings for the off-label indication of docetaxel for ovarian cancer. DRUGDEX describes the evidence as “inconclusive” and rates it in the second tier. NCCN also places the evidence in its second tier. Only NCCN cites recent Phase III studies; DRUGDEX and USP-DI cite older Phase II studies, while Facts & Comparisons and Clinical Pharmacology cite only review articles or textbooks.
- Recommendation statements: DRUGDEX and NCCN use an evidence rating for the off-label indication. DRUGDEX lists the indication as Class IIb, “Recommended in some cases,” while NCCN endorses the indication based on non-uniform agreement with no major disagreement that the indication is appropriate, except for use in recurrent disease, where they note uniform consensus that the indication is appropriate. USP-DI lists the off-label use under the “Accepted” category. Facts & Comparisons and Clinical Pharmacology make no further qualification of the listing.
- Toxicity: Toxicities related to docetaxel are reported in most of the compendia, but none notes toxicities specifically in patients with ovarian cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include ovarian cancer as an off-label indication for docetaxel. It emphasizes well-designed, controlled, published studies, but does not cite any of the 19 published Phase II or III studies identified in the EPC review. The last update was 1/10/06, but 2005 and prior data, including three Phase III trials, are not cited.
- USP-DI specifies that it includes off-label indications, and it does include ovarian cancer as an off-label indication for docetaxel. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. Five citations are listed, of which three are classified as Phase II; the Phase III trial identified in the EPC review is not cited. The last update was 11/28/05; all of the citations identified by the EPC are prior to this date.
- DRUGDEX specifies that it includes off-label indications, and it does include ovarian cancer as an off-label indication for docetaxel. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites nine citations, including Phase I and II trials, a case report, and two reviews. However, it does not cite the Phase III trial identified in the EPC review. The date of the last update was not reported, but 2005 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes ovarian cancer as an off-label indication for docetaxel. It emphasizes Phase II, III, and IV studies with over 30 subjects, but cites only non-peer-reviewed publications. The date of the last update is not stated, but the most recent study cited was from 1998.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is an off-label indication for docetaxel in ovarian cancer as per the guideline. The last update was 1/13/05, and 2004 data are cited. The listing cites Phase III trials exclusively; however, two of the three trials cited used paclitaxel rather than docetaxel. These were cited in a statement supporting “taxanes”; we interpreted this to be using paclitaxel studies as indirect evidence supporting use of docetaxel.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes ovarian cancer as an off-label indication for docetaxel. It emphasizes prospective trials, but cites only a 1997 review of Phase II prospective clinical trials.174 The last update was 11/15/05; however, none of the Phase II trials published since the 1997 review are cited, nor is the 2004 Phase III trial identified in the EPC review.

## Gemcitabine (Gemzar®) for Biliary Tract Cancer

Gemcitabine is a nucleoside analog with therapeutic indications for treatment of metastatic breast cancer (in combination with paclitaxel) after failure of prior anthracycline-containing adjuvant chemotherapy; treatment of locally advanced or metastatic NSCLC (in combination with cisplatin); and treatment of locally advanced or metastatic pancreatic cancer previously treated with 5-fluorouracil. Gemcitabine is also used off-label for treatment of various other cancers including biliary tract or gallbladder cancer.

### Systematic Review by EPC

A total of 60 articles and abstracts were identified through the EPC literature search. Of these, 33 met the EPC inclusion criteria.

Table 10a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 8) reports details from each of the 29 articles and four abstracts. The literature includes 23 peer-reviewed Phase II trials (including one RCT and one non-randomized controlled trial) and one Phase I trial. There are no Phase III trials. The peer-reviewed studies included a total of 694 subjects with biliary tract or gallbladder cancer who received gemcitabine. All studies reported tumor response outcomes and adverse effects; almost all reported survival data. Only two case reports reported QoL data and only three reported data on symptom outcomes.

Table 10a Study types and outcomes reported – gemcitabine for biliary tract cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 29 | 694 | 1998–2005 | 29 | 25 | 2 | 3 | 28
Phase III | - | - | - | - | - | - | - | -
Phase II | 23 (79%) | 654 (94%) | 1998–2005 | 23 | 22 | - | 2 | 23
Phase I | 1 (3%) | 3 (<1%) | 2000 | 1 | - | - | - | 1
Other^a^ | 5 (17%) | 37 (5%) | 1998–2004 | 5 | 3 | 2 | 1 | 4
Abstracts^b^ | 4 | 147 | 2004–5 | 4 | 3 | - | - | 4

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Case report or retrospective review or unclear.

b Not considered further.

Peer-reviewed Phase III trials. No Phase III trials have been published.

Peer-reviewed Phase II trials. There were two comparative trials (one randomized) and 21 cohort trials that were peer-reviewed Phase II trials. Only the randomized trial compared gemcitabine (2000 mg/m^2^ in combination with mitomycin C) to an alternative treatment (capecitabine and mitomycin C). The study concluded that gemcitabine was inferior to capecitabine for response rate, progression-free survival, and overall survival.181 The study examined patients with ascertained non-resectable biliary tract cancer who had no prior palliative chemotherapy; the treatments were used as first line therapy. The non-randomized comparative trial compared gemcitabine monotherapy to gemcitabine and 5-FU.182

In the 23 trials that evaluated gemcitabine (including the non-randomized comparative trial), all of the patients had non-resectable and/or metastatic biliary tract cancer. Sixteen trials described patients who were either chemonaïve or for whom gemcitabine was first line therapy. Doses of gemcitabine used ranged from 800 to 2200 mg/m^2^, although 14 studies used 1000 mg/m^2^. Nine Phase II trials evaluated gemcitabine as monotherapy. The trials that used combination therapy included 5-FU, capecitabine, cisplatin, and leucovorin as combination agents. In 23 of 25 cohorts of patients, tumor response rates were reported; the highest complete response rate (13 percent) was found in a study of 30 patients.183 Partial response rates ranged from 0 to 55 percent; stable disease ranged from 7 to 46 percent; and disease progression ranged from 0 to 65 percent. Median overall survival ranged from 4.6 to 15.4 months. Quality of life and symptom relief were rarely reported. All studies discussed adverse effects.

### Compendia Listings

Treatment indication and toxicities. Table 10b summarizes the compendia’s discussions of the off-label use of gemcitabine for treatment of biliary tract cancer. Only DRUGDEX, Facts & Comparisons and USP-DI explicitly stated an off-label indication for the agent. NCCN discussed the use of gemcitabine for biliary tract cancer, but did not explicitly state whether the agent is indicated for biliary tract cancer. NCCN did not report on toxicities due to gemcitabine. All the compendia, regardless of whether they discussed biliary tract cancer, discussed toxicities related to gemcitabine use in cancer patients; however, none discussed gemcitabine-related toxicities specifically among patients being treated for biliary tract cancer.

Table 10b Summary of compendia listings – gemcitabine for biliary tract cancer

| AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Off-label indication explicitly stated | No | No | Yes | Yes | Unclear | Yes
Sub-category of indication (accepted or acceptance not established) | - | - | NR for this indication (available for only gallbladder cancer) | NR | NR | Accepted
Stage of cancers | - | - | “Biliary tract cancer” | “Biliary cancer” | “Cholangiocarcinoma and gallbladder cancer” | “Locally advanced, unresectable, or metastatic biliary tract and gallbladder”
Method of treatment (first line or other) | - | - | NR | NR | Other | NR
Routes of administration | - | - | Intravenous | Intravenous | Intravenous | Intravenous
Uses of the agent (monotherapy or combination) | - | - | NR | NR | Combination | NR
Comparator discussed (placebo, standard treatment, other agents) | - | - | No | No | No | No
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | - | NR | NR | NR | NR
Toxicity reporting | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: No | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: No Cancer-specific: No Severity: By organ: Frequency: | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | - | No | No | No | No
Number of evidence citations | - | - | 3 (+12)^a^ | 0 | 2 | 31
Range of years of citations | - | - | 1998–2002 | | 2001; 2004 | 1993–2002
Sources of evidence (abstracts/published articles) | - | - | Abstracts Published articles Reviews | | Published article Book update | Abstracts Published articles Reviews Package insert
Number of abstracts cited [years] | - | - | 5 [2000–2001] (excluding one incorrect citation) | | 0 | 13 [1993–2001]
Number of published articles cited [years] | - | - | 6 published articles [1999-2001] 3 Reviews [2000] 1 Reviewer consensus ballot [2002] | | 1 published article [2001] 1 book update [2004] | 16 published articles [1998–2001] 1 Review [2002] 1 package insert
Date of last update | 12/8/2005 | 11/9/2005 | 2006 | 2005 | 2006 | 9/14/2005

a Three articles cited; 12 additional articles included in the reference list.

Studies cited in compendia versus studies identified in EPC review. Only DRUGDEX and USP-DI provided an extensive list of references, which included primary peer-reviewed articles, abstracts, review articles, and the package insert for gemcitabine. DRUGDEX included only studies that were published prior to 2002 even though their latest update was in 2006. However, only two references were cited in the text for the off-label indication and one other for toxicity; the remainder were not cited but were simply included in the bibliography. USP-DI included four of the five studies found by the EPC’s evidence review that were published in 2001 or earlier (the apparent time range of the USP-DI review). Several publications that did not meet the EPC eligibility criteria were referenced, including package inserts, review articles, a book update, and non-English language publications. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 10c.

Table 10c Articles cited by compendia vs. articles identified by EPC – gemcitabine for biliary tract cancer

Reference | EPC | AHFS-DI | Clin Pharm | DRUGDEX | F & C | NCCN | USP-DI | Notes
Reviewed by compendia: | - | No | No | Yes | Yes | Yes | Yes | -
Phase III
(none)
Phase II
Alberts, 2005^184^ | x
Cho, 2005^185^ | x
Gelibter, 2005^186^ | x
Knox, 2005^187^ | x
Park, 2005^188^ | x
Thongprasert, 2005^189^ | x
Andre, 2004^190^ | x
Doval, 2004^183^ | x
Eng, 2004^191^ | x
Hsu, 2004^192^ | x
Kornek, 2004^181^ | x
Tsavaris, 2004^193^ | x
Lin, 2003^194^ | x
Malik, 2003^195^ | x
Murad, 2003^196^ | x
Kuhn, 2002^197^ | x
Gallardo, 2001^198^ | x
Gebbia, 2001 182 | x | | | * | | | x
Kubicka, 2001^199^ | x | | | * | | x | x
Penz, 2001^200^ | x | | | * | | | x
Raderer, 1999^201^ | x | | | * | | | x
Valencak, 1999^202^ | x | | | * | | | x | Same study
Mezger, 1998^203^ | x | | | x | | | x
Phase I/II
(none)
Phase I
Eckel, 2002^204^ | | | | | | | x | Mixed population
Zanon, 2000^205^ | x | | | | | | x
Other
Knox, 2004^206^ | x
Price, 2001^207^ | | | | | | | x | Review
Bokemeyer, 2000^208^ | | | | | | | x | German
Gallardo, 2000^209^ | | | | | | | x | Spanish^a^
Teufel, 2000^210^ | x | | | | | | x
Verderame, 2000^211^ | x | | | * | | | x
Castro, 1998^212^ | x | | | x | | | x
Gallardo, 1998^213^ | x | | | | | | x
Hejna, 1998^214^ | | | | x | | | x | Review
No. of Abstracts | 4 | | | 5 | | | 14^b^
Abstract Years | 04–05 | | | 01–02 | | | 93–01

a Reference incorrect in USP-DI.

b Several references were abstracts, but were not cited as such.

* Non-cited references.

Recommendations and supporting evidence. DRUGDEX notes that the recommended agent’s use in biliary tract cancer does not imply that it has been approved for labeled use by FDA. No other discussion of biliary tract cancer is made.

Facts & Comparisons notes that gemcitabine has an “Unlabeled use” for biliary tract cancer. No other discussion of biliary tract cancer is made. The on-line compendium does not include references.

NCCN discusses gemcitabine in its section on hepatobiliary cancers. Gemcitabine is offered as an option for primary treatment of gallbladder cancer that is either metastatic or unresectable, and for primary treatment of symptomatic, unresectable, or metastatic intrahepatic or extrahepatic cholangiocarcinoma. NCCN grades both recommendations as category 2A: “There is uniform NCCN consensus, based on lower level evidence including clinical experience, that the recommendation is appropriate.” However, only a single primary study specific to gemcitabine is referenced in the guideline.

USP-DI included biliary tract cancers in its list of cancers for which treatment is “Accepted.” The compendium specifies that it be indicated for specific tumor stages, as noted in Table 10b. Regarding dose, the compendium states, “Because several doses and regimens using gemcitabine are showing activity, no individual dose/regimen is listed.” No mention is made regarding whether gemcitabine is indicated for first line treatment or as monotherapy or in combination therapy. The effectiveness of the treatment is also not quantified. Notably, several of the references cited have errors regarding journal or page numbers.

Summary. Listings of gemcitabine for biliary tract cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Four of the six compendia (DRUGDEX, Facts & Comparisons, NCCN, and USP-DI) discuss gemcitabine for treatment of biliary tract cancer.
- Specificity of clinical information: To describe the cancer indication, those compendia that discuss the off-label use of gemcitabine in biliary tract cancer use different ad hoc nomenclatures (e.g., Facts & Comparisons uses “biliary cancer”; and USP-DI uses “locally advanced, unresectable, or metastatic biliary tract and gallbladder”) instead of using a standardized classification (such as WHO staging of cancers). Only NCCN describes which combinations of treatments are indicated, and none of the compendia describes the doses. In addition, none of the compendia quantifies the effects of treatment with gemcitabine.
- Evidence rating: No compendium provides an explicit evidence rating for the off-label indication of gemcitabine for biliary tract cancer, although NCCN uses an overall evidence rating of “lower evidence, including clinical experience” in its section on hepatobiliary cancers. Only DRUGDEX and USP-DI include extensive references, but these are reported only as lists of the available evidence.
- Recommendation statements: Only NCCN uses evidence rating for the off-label indication. It makes a weak recommendation, “options include,” based on lower level evidence. USP-DI lists the off-label use under the “Accepted” category and makes a weak recommendation, “indicated.” USP-DI also mentions the off-label use through passive discussion using cited references. DRUGDEX and Facts & Comparisons make no further mention on the off-label use of gemcitabine in biliary tract cancer.
- Toxicity: Toxicities related to gemcitabine are reported in most of the compendia, but none notes toxicities specifically in patients with biliary tract cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI is silent about the off-label indication. It does not include biliary cancer as an off-label indication for gemcitabine. There is no published Phase III study of gemcitabine in biliary cancer, thus the compendium adheres to its stated methodology which emphasizes well-designed, controlled, published studies.
- USP-DI specifies that it includes off-label indications, and in its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. It categorizes the off-label indication of gemcitabine for biliary tract cancer as “Accepted” despite a lack of Phase III studies, and cites several Phase II studies and reviews. It does not cite any of the post-2001 Phase II studies identified in the EPC review, although the date of the last update was 9/14/05.
- DRUGDEX specifies that it includes off-label indications, but it does not include biliary tract cancer as an off-label indication for gemcitabine. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only studies published before 2001, although the last update was in 2006.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes biliary cancer as an off-label indication for gemcitabine. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite any of the Phase II studies identified in the EPC review. The last update was in 2005, but data from 1998–2005 are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is an off-label indication for gemcitabine in biliary cancer as per the guideline, although this is not explicitly stated. The last update was in 2006, but 2005 data are not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it does not include biliary cancer as an off-label indication for gemcitabine. It emphasizes prospective trials, but does not cite any of the Phase I or II studies identified in the EPC review. The last update was on 11/09/05, but data from 1998–2005 are not cited.

## Gemcitabine (Gemzar®) for Bladder Cancer

As stated above, gemcitabine is a nucleoside analog with therapeutic indications for treatment of metastatic breast cancer (in combination with paclitaxel) after failure of prior anthracycline-containing adjuvant chemotherapy; treatment of locally advanced or metastatic NSCLC (in combination with cisplatin); and treatment of locally advanced or metastatic pancreatic cancer previously treated with 5-FUl. Gemcitabine is also used off-label for treatment of various other cancers including advanced and/or metastatic bladder cancer.

### Systematic Review by EPC

A total of 134 articles and abstracts were identified through the EPC literature search. Of these, 61 met the EPC inclusion criteria.

Table 11a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 9) reports details from each of the 46 articles and 15 abstracts. The literature includes one peer-reviewed Phase III article (RCT), 28 peer-reviewed Phase II trials (one RCT, one non-randomized comparative trial, and the remainder cohort studies), two Phase I/II trials, 12 Phase I trials, and three retrospective trials. The peer-reviewed studies included a total of 2484 subjects with bladder cancer who received gemcitabine. The majority of the studies reported tumor response outcomes, survival data, and adverse effects; only a handful reported data on QoL and symptom outcomes.

Table 11a Study types and outcomes reported – gemcitabine for bladder cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 46 | 2484 | 1994–2005 | 39 | 35 | 4 | 10 | 42
Phase III | 1 (2%) | 203 (8%) | 2000 | 1 | 1 | 1 | 1 | 1
Phase II | 28 (61%) | 1034 (42%) | 1997–2005 | 27 | 25 | 1 | 7 | 28
Phase I/II | 2 (4%) | 88 (4%) | 2002–2004 | 1 | 2 | - | - | 1
Phase I | 12 (26%) | 293 (12%) | 1994–2004 | 9 | 5 | - | - | 12
Other^a^ | 3 (7%) | 866 (35%) | 2002-5 | 1 | 2 | 2 | 2
Abstracts^b^ | 15 | 597 | 2004-5 | 15 | 8 | - | - | 15

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Case report or retrospective trials.

b Not considered further.

Peer-reviewed Phase III trials. There was one Phase III RCT215 evaluating the use of gemcitabine chemotherapy for bladder cancer. This trial was published in 2000 and compared first line therapy of gemcitabine (1000 mg/m^2^) and cisplatin combination regimen to standard treatment of MVAC. The study included patients with stage IV TCC, and concluded that both treatments had similar survival and tumor response rates. Gemcitabine was more tolerable, less toxic, and safer than the MVAC regimen. The 5-year followup of the same study216 reported similar long-term overall survival rates. The study advanced the role of gemcitabine as standard care in patients with locally advanced or metastatic TCC.

Peer-reviewed Phase II trials. There were two comparative Phase II trials. The first trial217 used gemcitabine in combination regimens with carboplatin and showed improved outcomes. The other was a randomized Phase II trial218 that used paclitaxel in combination with gemcitabine and cisplatin, and compared outcomes with the gemcitabine-cisplatin regimen. The study concluded that the addition of paclitaxel to the gemcitabine-cisplatin combination regimen increased toxicity among elderly patients 70 years and above.

There were 26 Phase II trials that evaluated gemcitabine use. The majority of the patients had advanced and/or metastatic bladder cancer. Nineteen of the trials described patients who were either chemonaïve or for whom gemcitabine was first line therapy. Doses of gemcitabine used ranged from 750 to 3000 mg/m^2^; the majority of the trials used 1000 mg/m^2^. Six trials evaluated gemcitabine as monotherapy. The combination therapy was used in 20 trials that included cisplatin, carboplatin, paclitaxel, docetaxel, vinorelbine, epirubicin, and epidoxorubicin. Tumor response was reported in 27 trials; the greatest complete response rate (32 percent) was found in a study of 49 patients that used 800 mg/m^2^ of gemcitabine in combination with paclitaxel and carboplatin.219 Partial response rates ranged from 9 to 47 percent; stable disease ranged from 9 to 42 percent, and disease progression ranged from 3 to 55 percent. The overall one-year survival rates in seven studies that reported this outcome ranged from 26 to 60 percent. Almost all studies reported median overall survival duration that ranged from 5 to 21 months. Quality of life was reported in one study, and seven studies reported symptom relief.

Peer-reviewed Phase I/II and I trials. There were two Phase I/II trials, and 12 Phase I trials that evaluated gemcitabine use. The majority of the patients had advanced and/or metastatic bladder cancer. Seven trials described patients who were either chemonaïve or for whom gemcitabine was first line therapy. Doses of gemcitabine used ranged from 10 to 2500 mg/m^2^; six trials used doses higher than 1000 mg/m^2^. Only three trials evaluated gemcitabine as monotherapy. The combination therapy was used in 11 trials that included cisplatin, carboplatin, oxaliplatin, paclitaxel, docetaxel, and ifosfamide. Tumor response was reported in 10 trials; the greatest complete response rate (28 percent) was found in a study of 41 patients that used 2500 mg/m^2^ of gemcitabine in combination with paclitaxel.220 Partial response rates were reported in three trials and ranged from 24 to 53 percent; stable disease was reported in one Phase I/II trial as 19 percent; and disease progression from the same trial was three percent. The overall 1-year survival rates in three studies that reported this outcome ranged from 65 to 100 percent. Virtually all studies reported median overall survival duration that ranged from 5 to 21 months. Quality of life was reported in one study, and no studies reported symptom relief.

### Compendia Listings

Treatment indication and toxicities. Table 11b summarizes the compendia’s discussions of the off-label use of gemcitabine for treatment of bladder cancer. All but one compendia explicitly stated bladder cancer as an off-label indication for the agent. NCCN discussed the use of gemcitabine for advanced and/or metastatic bladder cancer, but did not explicitly state whether the agent is indicated as an off-label use. NCCN did not report on toxicities due to gemcitabine. All the compendia discussed toxicities associated with gemcitabine chemotherapy, including severity of adverse effects, and which organs were affected. Only Clinical Pharmacology discussed frequency of adverse effects; AHFS-DI, Clinical Pharmacology, and DRUGDEX reported gemcitabine-related toxicities specifically among patients being treated for advanced and/or metastatic bladder cancer. AHFS-DI and Facts & Comparisons did not explicitly discuss the dose indicated for the off-label use of gemcitabine for bladder cancer.

Table 11b Summary of compendia listings – gemcitabine for bladder cancer

| AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Off-label indication explicitly stated | Yes | Yes | Yes | Yes | Unclear | Yes
Sub-category of indication (accepted or acceptance not established) | NR | NR | Efficacy: Adult, Evidence favors efficacy Recommendation: Adult, Class IIb Strength of Evidence: Adult, Category B | NR | Category 2A – lower level evidence and uniform consensus that the recommendation is appropriate “Considered” for gemcitabine + cisplatin “Investigational” for gemcitabine + paclitaxel | Accepted
Stage of cancers | “Advanced or metastatic cancer” | “Locally advanced or metastatic bladder cancer” | “Transitional cell carcinoma of bladder” | NR | “Locally advanced disease or limited metastatic recurrence” | “Metastatic bladder (urothelial) cancer”
Method of treatment (first line or other) | Other | NR | NR | NR | First line for gemcitabine + cisplatin Other for gemcitabine + paclitaxel | NR
Routes of administration | Intravenous | NR | Intravenous | IV | Intravenous | Intravenous
Uses of the agent (monotherapy or combination) | Monotherapy and combination | Combination | Combination | NR | Combination | NR
Comparator discussed (placebo, standard treatment, other agents) | Yes Standard treatment | Yes Standard treatment | Yes Standard treatment | No | Yes | No
Outcomes mentioned for the off-label use (survival, tumor response, adverse effects) | Median time to progressive disease Complete response rate Partial response rate Symptomatic improvement | Survival time Time to disease progression Time to treatment failure Response ratio compared with standard treatment | Overall Survival Time to disease progression Time to treatment failure Response ratio compared with standard treatment | NR | Survival response for gemcitabine + cisplatin Relapse or Noncomplete response as an indication for gemcitabine + paclitaxel | Complete response Partial response
Toxicity of the agents | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: No | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: No | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: No | Overall: No Cancer-specific: No Severity: By organ: Frequency: | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: No
Dose indicated for the off-label use (yes/no) | Not explicitly | Yes | Yes | No | Yes for gemcitabine + cisplatin No for gemcitabine + paclitaxel | Yes
Number of evidence citations | 8 | 1 | 2 (+1)^a^ | 0 | 2 for gemcitabine + cisplatin 0 for gemcitabine + paclitaxel | 6
Range of years of citations | 1994–2000 | 2000 | 1994–2000 | | 2000 | 1994–1998
Sources of evidence (abstracts/published articles) | Abstracts Published journal articles Reviews | Published journal article | Abstracts Published journal articles | | Published journal articles | Abstracts Published journal articles Panel responses Package insert
Number of abstracts cited [years] | 1 [1996] | 0 | 1 [1995] | | 0 | 1 [1995]
Number of published articles cited [years] | 5 journal articles [1994–2000] 2 reviews [2000; 1 NR] | 1 journal article for Gemcitabine + cisplatin [2000] | 1 journal article for Gemcitabine + cisplatin [2000] 1 Phase I trial [1994] | | 2 journal articles for gemcitabine + cisplatin [2000] | 3 journal articles [1994–1997] 1 panel responses to ballot [1998] 1 package insert Lily-U.S. [1996; 1998]
Date of last update | 12/8/2005 | 11/9/2005 | 2006 | 2005 | 2006 | 9/14/2005

a One abstract and one article cited; one additional article included in the reference list.

Studies cited in compendia versus studies identified in EPC review. Among the compendia that reported off-label use of gemcitabine for treatment of advanced and/or metastatic bladder cancer, only one (Facts & Comparisons) did not provide any reference lists. The other five provided up to eight references, which included primary peer-reviewed articles, abstracts, review articles, and the package insert for gemcitabine. For the peer-reviewed articles, AHFS-DI included five, Clinical Pharmacology included one, DRUGDEX included two, NCCN included one, and USP-DI included three of the 43 studies found by the EPC’s evidence review that were published between 1994 and 2004. There was only one215 common Phase III trial referenced across the four compendia – AHFS-DI, DRUGDEX, NCCN, and Clinical Pharmacology. Several publications that did not meet the EPC eligibility criteria were referenced, including package inserts and review articles. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 11c.

Table 11c Articles cited by compendia vs. articles identified by EPC – gemcitabine for bladder cancer

Reference | EPC | AHFS- DI | Clin Pharm | DRUGDEX | F & C | NCCN | USP-DI | Notes
Reviewed by compendia: | | Yes | Yes | Yes | Yes | Yes | Yes
Phase III
von der Maase, 2005^216^ | x
von der Maase, 2000^215^ | x | x | x | x | | x
Phase II
Ardavanis, 2005^221^ | x
Artz, 2005^222^ | x
Hainsworth, 2005^223^ | x
Li, 2005^224^ | x
Lorusso, 2005^218^ | x
Srinivas, 2005^225^ | x
Castagneto, 2004^226^ | x
Hoshi, 2004^217^ | x
Kaufman, 2004^227^ | x
Linardou, 2004^228^ | x
Gitlitz, 2003^229^ | x
Mallick, 2003^230^ | x
Turkolmez, 2003^231^ | x
Albers, 2002^232^ | x
Neri, 2002^233^ | x
Pectasides, 2002^234^ | x
Ricci, 2002^235^ | x
Hussain, 2001^219^ | x
Meluch, 2001^236^ | x
Carles, 2000^237^ | x
Delord, 2000^238^ | x
Khaled, 2000^239^ | x
Lorusso, 2000^240^ | x | | | | | x
Moore, 1999^241^ | x
Lorusso, 1998^242^ | x
Moore, 1997^243^ | x | x | | | | | x
Stadler, 1997^244^ | x | x | | | | | x
Phase I/II
Hussain, 2004^245^ | x
Bellmunt, 2002^246^ | x
Phase I
Sangar, 2005^247^ | x
Herman, 2004^248^ | x
Kent, 2004^249^ | x
Caffo, 2003^250^ | x
Culine, 2003^251^ | x
DiPaola, 2003^252^ | x
Meliani, 2003^253^ | x
Bellmunt, 2001^254^ | x
Bhargava, 2001^255^ | x
Millikan, 2001^256^ | x
Sternberg, 2001^220^ | x
Pollera, 1994^257^ | x | x | | * | | | x
Other
Bamias, 2005^258^ | x
Roychowdhury, 2003^259^ | x
Stadler, 2002^260^ | x
Anonymous, 2000^261^ | | x | | | | | | Review
Roth, 1996^262^ | | x | | | | | | Review
No. of Abstracts | 15 | 1 | 0 | 1 | 0 | 0 | 1
Abstract Years | 04–05 | 96 | | 95 | | | 95

* Non-cited reference.

Recommendations and supporting evidence. AHFS-DI states that “gemcitabine is an active agent that is used alone or in combination therapy for the treatment of advanced or metastatic bladder cancer” among its list of off-label uses in cancer. No explicit mention is made regarding the indicated dose and line of treatment. The effectiveness of the treatment is discussed and compared with standard treatment for the cancer. The compendium does not explicitly make any recommendation on the off-label use of gemcitabine in bladder cancer.

Clinical Pharmacology describes one Phase III trial that used gemcitabine for an off-label and post-first line use in combination regimen “for the treatment of locally advanced or metastatic bladder cancer.” The dose and effectiveness of the treatment used data from the cited study.

DRUGDEX reports combination therapy use of gemcitabine in “transitional cell carcinoma of bladder” and discusses one Phase III trial to support the indicated off-label use. The compendium indicates gemcitabine use as combination therapy; no mention is made regarding whether gemcitabine is indicated for first line or post-first line treatment. It specifies that the “evidence favors efficacy” for the indicated use.

Facts & Comparisons notes that gemcitabine has an “unlabeled use” for “bladder cancer.” No other discussion of gemcitabine use in bladder cancer is made. The on-line compendium does not include references.

NCCN discusses gemcitabine in its section on bladder cancers. The combination therapy of gemcitabine-cisplatin is “considered” as “standard first line choice” for most patients with recurrent metastatic or locally advanced bladder cancer, and the combination therapy of gemcitabine-paclitaxel is “considered” as “investigational.” It grades both recommendations as category 2A: “There is uniform NCCN consensus, based on lower level evidence including clinical experience, that the recommendation is appropriate.” The compendium “advises” gemcitabine for salvage therapy and for use as monotherapy among patients who do not tolerate a cisplatin-based regimen. Regarding dose, the compendium mentions 1000 mg/m^2^ once a week for 4 weeks. The effectiveness of the treatment is discussed for both combination regimens and two primary studies specific to gemcitabine use are cited.

USP-DI includes “metastatic bladder (urothelial) carcinoma” among its list of cancers for which the modality of treatment with gemcitabine is “accepted.” Regarding dose, the compendium recommends 1000 to 1200 mg/m^2^ once a week for 3 weeks. The compendium does not indicate gemcitabine use as monotherapy or combination therapy; no mention is made regarding whether gemcitabine is indicated for first line or post-first line treatment. The effectiveness of the treatment is discussed for tumor response rates. No evidence rating for the indicated use is reported, whereas the rating was used in ovarian cancer.

Summary. Listings of gemcitabine for bladder cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: All six compendia discuss gemcitabine for treatment of advanced and/or metastatic bladder cancer.
- Specificity of clinical information: To describe the cancer indication, the compendia use different ad hoc nomenclatures (e.g., AHFS-DI uses “advanced or metastatic bladder cancer,” and NCCN uses “locally advanced disease or limited metastatic recurrence”) instead of using a standardized classification (such as WHO staging of cancers). Only NCCN describes explicitly which combinations and modalities of treatments are indicated. Only three of the compendia (DRUGDEX, NCCN, and USP-DI) describe doses. In addition, the quantification of the effectiveness of treatment with gemcitabine varied across the compendia.
- Evidence rating: Only two compendia (DRUGDEX and NCCN) provide explicit evidence ratings for the off-label use of gemcitabine for bladder cancer; NCCN, however, uses an overall evidence rating as “lower level evidence, including clinical experience” in its section on bladder cancers. No compendium cites trials published after 2000, and only four (AHFS-DI, Clinical Pharmacology, DRUGDEX, and NCCN) cite the Phase III trial published in 2000.
- Recommendation statement: DRUGDEX makes a recommendation rating of class IIb, “treatment may be useful and is indicated in some, but not most cases,” based on the strength of evidence category B, for the off-label use. NCCN makes a weak recommendation – i.e., “consider” and “advise” – based on lower level evidence. AHFS-DI, USP-DI, and Clinical Pharmacology mention the off-label use through passive discussion using cited references. Only Facts & Comparisons does not describe details regarding the off-label use of gemcitabine in bladder cancer.
- Toxicity: Toxicities related to gemcitabine are reported in most of the compendia, and AHFS-DI, Clinical Pharmacology, and DRUGDEX note toxicities specifically in patients with bladder cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it includes bladder cancer as an off-label indication for gemcitabine. It emphasizes well-designed, controlled, published studies, but does not cite the published Phase III study identified in the EPC review. The last update was 12/8/05, but 2005 data, including the Phase III study, are not cited.
- USP-DI specifies that it includes off-label indications, and it does include bladder cancer as an off-label indication for gemcitabine. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff; it does not cite the Phase III study identified in the EPC review. The last update was 9/14/05, but data published in 2000 and 2005 are not cited.
- DRUGDEX specifies that it includes off-label indications, and it does include bladder cancer as an off-label indication for gemcitabine. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only an old narrative review and does not cite the Phase III study identified in the EPC review. The date of the last update was 2006, but 2005 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes bladder cancer as an off-label indication for gemcitabine. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite the several clinical trials identified in the EPC review that meet these criteria, including two Phase III studies. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. As per the guideline, there is not an explicit mention of an off-label indication for gemcitabine in bladder cancer. Instead, the NCCN documents use the terms “considered” for gemcitabine plus cisplatin, and “investigational” for gemcitabine plus paclitaxel. The last update was in 2006, but 2005 data are not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes bladder cancer as an off-label indication for gemcitabine. It emphasizes prospective trials, but does not cite several trials identified in the EPC review, including one of two Phase III studies. The last update was 11/9/05, but early 2005 data are not cited.

## Gemcitabine (Gemzar®) for Ovarian Cancer

As stated above, gemcitabine is a nucleoside analog with therapeutic indications for treatment of metastatic breast cancer (in combination with paclitaxel) after failure of prior anthracycline-containing adjuvant chemotherapy; treatment of locally advanced or metastatic NSCLC (in combination with cisplatin); and treatment of locally advanced or metastatic pancreatic cancer previously treated with 5-FU. Gemcitabine is also used off-label for treatment of various other cancers including advanced and/or metastatic ovarian cancer.

### Systematic Review by EPC

A total of 414 articles and abstracts were identified through the EPC literature search. Of these, 48 met the EPC inclusion criteria.

Table 12a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 10) reports details from each of the 42 articles and six abstracts. The literature includes two peer-reviewed Phase III articles (both randomized controlled trials), 21 peer-reviewed Phase II trials (all cohort studies), three Phase I/II trials, and 10 Phase I trials. The peer-reviewed studies included a total of 1948 subjects with ovarian cancer who received gemcitabine. All studies reported tumor response outcomes and adverse effects; almost all reported survival data. Only two Phase III trials and three Phase II trials reported quality-of-life data and only two (both Phase III trials) reported data on symptom outcomes.

Table 12a Study types and outcomes reported – gemcitabine for ovarian cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 42 | 1948 | 1998–2006 | 42 | 29 | 5 | 2 | 39
Phase III | 2 (5%) | 266 (14%) | 2005–2006 | 2 | 2 | 2 | 2 | 2
Phase II | 22 (52%) | 986 (51%) | 1994–2005 | 22 | 17 | 3 | - | 21
Phase I | 13 (31%) | 345 (18%) | 1994–2004 | 13 | 7 | - | - | 13
Other | 5 (12%) | 351 (18%) | 1997–2004 | 5 | 3 | - | - | 3
Abstracts^a^ | 6 | 129 | 2004–2005 | 6 | 5 | - | - | 6

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Not considered further.

Peer-reviewed Phase III trials. There were two Phase III RCTs evaluating the use of gemcitabine chemotherapy for ovarian cancer. The first Phase III trial263 was published in 2005 and compared post-first line therapy of gemcitabine (1000 mg/m^2^ in combination with carboplatin) to the alternative monotherapy of carboplatin. The study included patients with all stages of ovarian cancers including advanced ovarian cancer. The study concluded that gemcitabine in combination had better progression-free survival, higher response rate, improved symptoms with improved QoL, and an acceptable level of hematological toxicity compared to carboplatin monotherapy. The second study was a multicenter trial from Europe published in early 2006 that compared the sequential schedule of single-agent carboplatin followed by docetaxel only vs a docetaxel-gemcitabine combination as first line therapy. The study used different dosages (850 to 1250 mg/m^2^) of gemcitabine in two of the three arms in combination with docetaxel. This study had higher rates of dyspnea in gemcitabine arms and failed feasibility completion rates.

Peer-reviewed Phase II trials. There were 22 Phase II trials (all cohort studies) that evaluated gemcitabine. The majority of the trials included patients with advanced and/or metastatic ovarian cancer. Five of the trials described patients who were either chemonaïve or for whom gemcitabine was first line therapy. Doses of gemcitabine ranged from 800 to 1250 mg/m^2^; eight studies used 800 mg/m^2^ and eight used 1000 mg/m^2^. Eight trials evaluated gemcitabine as monotherapy. Combination therapy was used in 14 trials and included cisplatin, carboplatin, paclitaxel, doxorubicin, and topotecan. Tumor response was reported in 21 trials; the greatest complete response rate (60 percent) was found in a study of 20 patients that used 800 mg/m^2^ of gemcitabine in combination with paclitaxel and carboplatin.264 Partial response rates ranged from 5 to 50 percent; stable disease ranged from 3 to 52 percent; and disease progression ranged from 0 to 50 percent. The overall 1-year survival rates ranged from 40 to 81 percent in seven studies that reported. Median overall survival ranged from 6 to 44 months. QoL was reported in three studies, and no studies reported symptom relief.

Peer-reviewed Phase I/II or I trials. There were 13 Phase I/II trials or Phase I trials that evaluated gemcitabine use in advanced and/or metastatic ovarian cancer. Three of the trials described patients who were either chemonaïve or for whom gemcitabine was first line therapy. Doses of gemcitabine ranged from 200 to 1250 mg/m^2^; eight studies used 800 mg/m^2^ and eight used 1000 mg/m^2^. Only one trial evaluated gemcitabine as monotherapy. Combination therapy was used in 14 trials and included cisplatin, carboplatin, paclitaxel, docetaxel, doxorubicin, rubitecan, and topotecan. Tumor response was reported in 12 trials; the greatest complete response rate (85 percent) was found in a study of 57 patients that used 800 mg/m^2^ of gemcitabine in combination with paclitaxel and carboplatin.265 Partial response rates ranged from 6 to 41 percent; stable disease ranged from 6 to 38 percent; and disease progression ranged from 6 to 57 percent. The overall 1-year survival rates ranged from 61 to 92 percent in two studies that reported the data. Median overall survival ranged from 6 to 44 months. No studies reported QoL or symptom relief.

### Compendia Listings

Treatment indication and toxicities. Table 12b summarizes the compendia’s discussions of the off-label use of gemcitabine for treatment of advanced and/or metastatic ovarian cancer. Only AHFS-DI, Clinical Pharmacology, DRUGDEX, Facts & Comparisons, and USP-DI explicitly stated an off-label indication for the agent. NCCN discussed the use of gemcitabine for advanced and/or metastatic ovarian cancer but did not explicitly state whether the agent is indicated as an off-label use. NCCN did not report on toxicities due to gemcitabine. All other compendia discussed toxicities associated with gemcitabine chemotherapy, including severity of adverse effects, and which organs were affected; however, only Clinical Pharmacology, DRUGDEX, and Facts & Comparisons state the frequency of adverse effects and gemcitabine-related toxicities specifically among patients treated for advanced and/or metastatic ovarian cancer. Only USP-DI indicated the dose for the off-label use of gemcitabine for this cancer.

Table 12b Summary of compendia listings – gemcitabine for ovarian cancer

| AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Off-label indication explicitly stated | Yes | Yes | Yes | Yes | Unclear | Yes a
Sub-category of indication (accepted or acceptance not established) | Investigational | NR | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | NR | Accepted | Accepted
Stage of cancers | “Advanced epithelial ovarian cancer” | “Ovarian cancer” | “Ovarian cancer” | “Ovarian cancer” | “Recurrent ovarian cancer” | “Advanced or relapsed epithelial ovarian carcinoma”
Method of treatment (first line or other) | Other | Other | Other | NR | Other | Unclear
Routes of administration | Intravenous | Intravenous | Intravenous | Intravenous | NR | Intravenous
Uses of the agent (monotherapy or combination) | Monotherapy | Combination | Monotherapy or combination with other agents | NR | Combination | Monotherapy or combination with other agents
Comparator discussed (placebo, standard treatment, other agents) | No | No | No | No | No | No
Outcomes mentioned for the off-label use (survival, tumor response, other) | Objective responses | Complete responses Partial responses Median survival Median progression-free survival | Response rate | NR | Response rate | NR
Toxicity reporting | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: No | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: No | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: No Cancer-specific: No Severity: No By organ: No Frequency: No | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: No
Dose indicated for the off-label use | No | “Not established” | Yes | No | No | Yes
Number of evidence citations | 6 | 4 | 3 (+1)^b^ | 0 | 2 | 13
Range of years of citations | 1994–2001 | 2003–2004 | 1996–2000 | | 1994; 2005 | 1994–1999
Sources of evidence (abstracts/published articles) | Published articles Review Cancer database | Published articles | Published articles Abstracts Review | | Published articles | Published articles Package insert Abstracts Review Manufacturer’s comment
Number of abstracts cited [years] | 0 | 0 | 1 [1996] | | 0 | 6 [1998–1999]
Number of published articles cited [years] | 4 published articles [1994–1999] 1 Review [2000] 1 Cancer database [2001] | 4 published articles [2003–2004] | 3 reviews [1997–2000] | | 2 published articles [1994; 2005] | 4 published articles [1994–1998] 1 package insert [1996–1998] Abstracts [1998–1999] Review [1999] Manufacturer’s comment [1999]
Date of last update | 12/8/2005 | 11/9/2005 | 2006 | 2005 | 2006 | 9/14/2005

a Evidence rating IIID

b Three articles cited; one additional review article included in the reference list.

Studies cited in compendia versus studies identified in EPC review. Among all compendia that reported the off-label use of gemcitabine for treatment of advanced and/or metastatic ovarian cancer, only Facts & Comparisons did not provide any reference lists. The other five compendia provided up to 13 references, which included primary peer-reviewed articles, abstracts, review articles, and the package insert for gemcitabine. For the peer-reviewed articles, AHFS-DI included four, Clinical Pharmacology included three, DRUGDEX included two, NCCN included one, and USP-DI included three of the 42 studies found by the EPC’s evidence review that were published between 1994 and 2004, with only one266 common reference across the three compendia (AHFS-DI, NCCN, and USP-DI). Several publications that did not meet the EPC eligibility criteria were referenced, including package inserts, review articles, and database review. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 12c.

Table 12c Articles cited by compendia vs. articles identified by EPC – gemcitabine for ovarian cancer

Reference | EPC | AHFS- DI | Clin Pharm | DRUGDEX | F & C | NCCN | USP-DI | Notes
Reviewed by compendia: | - | Yes | Yes | Yes | Yes | Yes | Yes | -
Phase III
Vasey, 2006^267^ | x
Pfisterer, 2005^263^ | x
Phase II
du Bois, 2005^268^ | x
Ferrandina, 2005^269^ | x
Gupta, 2005^270^ | x
Kose, 2005^271^ | x
Garcia, 2004^272^ | x
Harries, 2004^273^ | x
Liu, 2004^264^ | x
Papadimitriou, 2004^274^ | x
Bauknecht, 2003^275^ | x
Belpomme, 2003^276^ | x | | x
D’Agostino, 2003^277^ | x
D’Agostino, 2003^278^ | x | | x
Markman, 2003^279^ | x
Nagourney, 2003^280^ | x
Nogue, 2002^281^ | x
Sehouli, 2002^282^ | x
Underhill, 2001^283^ | x
Silver, 1999^284^ | x
von Minckwitz, 1999^285^ | x | x
Friedlander, 1998^286^ | x | x | | | | | x
Lund, 1995^287^ | x
Lund, 1994^266^ | x | x | | | | x | x
Phase I/II
Barlow, 2004^288^ | x
Sabbatini, 2004^289^ | x
Greggi, 2001^290^ | x
Phase I
Look, 2004^291^ | x
Micha, 2004^265^ | x
Berkenblit, 2003^141^ | x
Sehouli, 2003^292^ | x
D’Agostino, 2002^293^
Fracasso, 2002^294^ | x
du Bois. 2001^295^ | x
Iaffaioli, 2000^296^ | x
Pignata, 2000^297^ | x
Shapiro, 1996^298^ | x | x | | | | | x
Other
Rose, 2005^299^ | | | | | | x | | Review
Geisler, 2004^300^ | x | | x
Markman, 2004^123^ | x
Prasad, 2004^301^ | x
Tewari, 2004^302^ | x
Villella, 2004^303^ | x
Bilgin, 2003^304^ | | | x | | | | | Not available
CancerNet/PDQ, 2001^305^ | | x | | | | | | Database
Anonymous, 2000^261^ | | x | | | | | | Review
Gerson, 2000^306^ | | | | * | | | | Review
Eisenhauer, 1997^307^ | x
Kaufmann, 1997^308^ | | | | x | | | | Review
Pedersen, 1997^309^ | | | | x | | | | Review
Martin, 1996^310^ | | | | | | | x | Review
No. of Abstracts | 6 | 0 | 0 | 1 | 0 | 0 | 6
Abstract Years | 04–05 | | | 96 | | | 98–99

* Non-cited reference.

Recommendations and supporting evidence. AHFS-DI states that “gemcitabine is an active agent in ovarian cancer and currently is being investigated for use in the treatment of advanced epithelial ovarian cancer.” The compendium cites Phase II trials for gemcitabine use as monotherapy and for post-first line treatment; no mention is made regarding the indicated dose. The effectiveness of the treatment is discussed, and the compendium identifies the need for further studies to establish the role of gemcitabine in ovarian cancer treatment.

Clinical Pharmacology evaluates gemcitabine use for off-label and post-first line use in ovarian cancer. The compendium discusses gemcitabine use in combination therapy for the treatment of ovarian cancer, with dose for the treatment as “not established.” The effectiveness of the treatment is discussed from cited studies.

DRUGDEX includes “ovarian cancer” among its list of cancers for the off-label use of gemcitabine. It specifies that the “evidence for efficacy is inconclusive” for the indicated use. While the compendium indicates gemcitabine use as monotherapy or in combination therapy, no mention is made regarding the indicated dose and whether gemcitabine is used for first line or post-first line treatment.

Facts & Comparisons notes gemcitabine as an “Unlabeled use” for the treatment of “ovarian cancer.” No other discussion of gemcitabine use in ovarian cancer is made. The on-line compendium does not include references.

NCCN discusses gemcitabine use in its section on ovarian cancers. It is offered as an “acceptable” modality for treatment of recurrent epithelial ovarian cancer that is either platinum-sensitive or resistant. It grades both recommendations as category 2A: “There is uniform NCCN consensus, based on lower level evidence including clinical experience, that the recommendation is appropriate.” The effectiveness of the treatment cited a response rate of 19 percent from a single primary study specific to gemcitabine use.

USP-DI included “advanced and/or relapsed epithelial ovarian carcinoma” among its list of cancers for which the use of gemcitabine is “Accepted.” It specifies the indicated use as “reasonable medical therapy at some point in the management of patients with advanced or relapsed epithelial ovarian carcinoma.” Regarding dose, the compendium describes 800 to 1250 mg/m^2^ once a week for 2 or 3 weeks. While the compendium indicates gemcitabine use as monotherapy or in combination therapy, no mention is made regarding whether gemcitabine is used for first line or post-first line treatment. The effectiveness of the treatment is also not discussed. Notably, the evidence rating for the indicated use is IIID.

Summary. Listings of gemcitabine for ovarian cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: All six compendia discuss gemcitabine for treatment of advanced and/or metastatic epithelial ovarian cancer.
- Specificity of clinical information: To describe the cancer indication for which the agent is indicated as an off-label use, the compendia that discuss gemcitabine use different ad hoc nomenclatures rather than a standardized classification (such as WHO staging of cancers). Only DRUGDEX, NCCN, and Clinical Pharmacology describe which combinations of treatments are indicated, and only USP-DI describes appropriate doses. In addition, the description of the effectiveness of treatment with gemcitabine varies across the compendia.
- Evidence rating: Only two compendia (DRUGDEX and USP-DI) provide explicit evidence ratings for the off-label use of gemcitabine for ovarian cancer. DRUGDEX rates the evidence as category B, while USP-DI rates it as IIID. Only USP-DI lists more than 10 references.
- Recommendation statements: DRUGDEX makes a class III recommendation, “treatment is not useful and should be avoided,” for the off-label indication. NCCN uses an evidence rating for the off-label indication and makes a weak recommendation, “options,” based on lower level evidence. AHFS-DI and Clinical Pharmacology mention the off-label use through passive discussion using cited references. Facts & Comparisons does not describe in any detail the off-label use of gemcitabine in ovarian cancer.
- Toxicity: Toxicities related to gemcitabine are reported in most of the compendia, but only DRUGDEX and Clinical Pharmacology note toxicities specifically in patients with ovarian cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it includes ovarian cancer as an off-label indication for gemcitabine. It emphasizes well-designed, controlled, published studies, but does not cite the 2005 Phase III study identified in the EPC review. The last update was 12/08/05, but 2005 data, including the Phase III study, are not cited.
- USP-DI specifies that it includes off-label indications, and it does include ovarian cancer as an off-label indication for gemcitabine. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. It does not cite the 2005 Phase III study identified in the EPC review. The last update was 9/14/05, but the Phase III study published earlier that year is not cited.
- DRUGDEX specifies that it includes off-label indications, and it does include ovarian cancer as an off-label indication for gemcitabine. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only old narrative reviews and does not cite the 2005 Phase III study identified in the EPC review. The date of the last update was 2006, but 2005 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes ovarian cancer as an off-label indication for gemcitabine. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite the Phase III study identified in the EPC review. The date of the last update is not stated, but 2005 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is no explicit off-label indication for gemcitabine in ovarian cancer as per the guideline. The last update was in 2006, but 2005 data are not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes ovarian cancer as an off-label indication for gemcitabine. It emphasizes prospective trials, but does not cite the one Phase III study identified in the EPC review. The date of the last update was 11/9/05, but early 2005 data are not cited.

## Rituximab (Rituxan®) for Chronic Lymphocytic Leukemia

Rituximab is a monoclonal antibody with therapeutic indications for treatment of relapsed or refractory low-grade or follicular CD20-positive, B-cell non-Hodgkin’s lymphoma. Rituximab has also been evaluated for treatment of chronic lymphocytic leukemia (CLL).

### Systematic Review by EPC

A total of 164 articles and abstracts were identified through the EPC literature search. Of these, 43 met the EPC inclusion criteria.

Table 13a describes the study types of the included studies and the outcomes reported. Appendix B (Evidence Table 11) reports details from each of the 33 articles and 10 abstracts. The peer-reviewed literature includes 13 Phase II trials (one randomized and one non-randomized trial); five Phase I/II trials; and six Phase I trials (one non-randomized comparative trial). There were no Phase III trials. The 33 peer-reviewed studies included a total of 974 subjects with CLL who received rituximab. Tumor response, survival, and adverse effects data were reported in at least 85 percent of the trials and case reports. One trial and five case reports included symptom outcomes data, and no studies reported on quality of life.

Table 13a Study types and outcomes reported – rituximab for chronic lymphocytic leukemia

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 33 | 974 | 1999–2005 | 30 | 28 | | 6 | 29
Phase III | - | - | - | - | - | - | - | -
Phase II | 13 (39%) | 373^a^ (38%) | 1999–2005 | 13 | 11 | - | - | 12
Phase I/II | 5 (15%) | 467 (48%) | 2001–2005 | 5 | 4 | - | 1 | 5
Phase I | 5 (15%) | 110 (11%) | 1999–2004 | 5 | 4 | - | | 5
Other^b^ | 10 (30%) | 24 (2%) | 1999–2005 | 7 | 10 | - | 5 | 7
Abstracts^c^ | 10 | 212 | 2004–2005 | 9 | 5 | - | | 9

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Includes an unknown percentage of 13 patients who received rituximab in one study.

b Case reports or retrospective case series.

c Not considered further.

Peer-reviewed Phase III trials. No Phase III trials have been published.

Peer-reviewed Phase II trials. There were two comparative trials (one randomized) and 11 cohort studies that were peer-reviewed Phase II trials. The randomized trial consisted of concurrent therapies of rituximab and fludarabine vs sequential treatment of fludarabine followed by rituximab for patients with no prior treatment for CLL.311 Both arms had rituximab consolidation therapy, and similar toxicities were reported. The arm with concurrent therapies had an overall response rate of 90 percent. The non-randomized study included 27 patients with non-Hodgkin's lymphomas who were undergoing autologous stem cell transplantation. It was not reported which of the 13 with CLL received rituximab with high-dose chemotherapy or high-dose chemotherapy alone.312 All studies used the dosage of 375 mg/m^2^. Six of the cohort trials evaluated rituximab as monotherapy. Three trials described patients who were chemonaïve or for whom rituximab was first line therapy, and two trials enrolled patients with a varied history of treatment. In 10 of 13 cohort studies that reported complete response rates, the greatest complete response rate (78 percent) was found in a study of 65 patients.313 Partial response ranged from 0 to 55 percent; stable disease ranged from 0 to 83 percent; and disease progression ranged from 0 to 32 percent.

Peer-reviewed Phase I/II trials. There were five cohort trials including a three-arm study that were peer-reviewed Phase I/II trials. Four studies reported dosages of 375 mg/m^2^ and two studies reported escalating dosages of rituximab from 125 to 250, and 375 mg/m^2^, and from 375 to 500 mg/m2. The three-arm study dosing was 250 or 375 mg/m^2^ with no co-intervention. One of the cohort trials evaluated rituximab as monotherapy. One study enrolled patients who were chemonaïve and another study reported over half of the patients with a prior history of chemotherapy. Complete response was reported in all five trials ranging from less than four to 70 percent in one study of 224 patients.314 Quality of life and symptom relief were not reported. All studies discussed adverse effects.

Peer-reviewed Phase I trials. There were six peer-reviewed Phase I trials including one non-randomized comparison and one retrospective three-arm cohort. Five of the cohort trials evaluated rituximab as monotherapy. All of the studies except for the retrospective study included patients who had prior chemotherapy and also reported response and survival data. Complete response data was generally not given except in one study and as part of overall response in another. Partial response ranged from 9 to 38 percent. Quality of life and symptom relief were not reported.

### Compendia Listings

Treatment indication and toxicities. Table 13b summarizes the compendia’s discussions of the off-label use of rituximab for treatment of chronic lymphocytic leukemia. Three compendia (DRUGDEX, Clinical Pharmacology and USP-DI) explicitly stated CLL as an off-label indication for the agent. NCCN discussed the use of rituximab for CLL and small lymphocytic lymphoma (SLL), but did not explicitly state whether the agent is indicated as an off-label use. NCCN did not report on toxicities due to rituximab. All other compendia discussed toxicities associated with rituximab chemotherapy, including severity of adverse effects, and which organs were affected. All compendia, except for NCCN and USP-DI, discussed frequency of adverse effects; AHFS-DI, DRUGDEX, USP-DI, and Facts & Comparisons reported rituximab-related toxicities specifically among patients being treated for CLL. Only Clinical Pharmacology discussed the dose indicated for the off-label use of rituximab for CLL.

Table 13b Summary of compendia listings – rituximab for chronic lymphocytic leukemia

| AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Off-label indication explicitly stated | No | Yes | Yes | No | Unclear | Yes
Sub-category of indication (accepted or acceptance not established) | - | Implies experimental | Efficacy: Adult, Evidence favors efficacy Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | - | NCCN Category 2A^a^ | Accepted
Stage of cancers | - | NR | “Chronic lymphoid leukemia” | - | All (categorized by stage) | NR
Method of treatment (first line or other) | - | Unclear | First line | - | First line and Second line | 1^st^ line and relapsed/refractory
Routes of administration | - | Intravenous | Intravenous | - | Intravenous | “Consult the medical literature and/or experts”
Uses of the agent (monotherapy or combination) | - | Monotherapy Combination therapy | Combination | - | Combination | Combination (1st line) Unclear (relapsed/refractory)
Comparator discussed | - | No | No | - | No | No
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | Overall response rate Complete response rate | Overall response rate | - | NR | Overall response rate Complete response rate
Toxicity reporting | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes (Death for CLL) Frequency: Yes | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes (Death for CLL) Frequency: Yes | Overall: No Cancer-specific: No Severity: By organ: Frequency: | Overall: Yes Cancer-specific: Yes Severity: No By organ: Yes (Death for CLL) Frequency: No
Dose indicated for off-label use | - | Yes | No | - | No | No
Number of evidence citations | 1 | 2 | 12 (+6)^b^ | 1 c | 1 | 29
Range of years of citations | 2004 | 2000–2001 | 1999–2001 | 2001 | 2003 | 1999–2005 d
Sources of evidence (abstracts/published articles) | Prescribing information | Published article Abstract | Published articles Abstracts Case reports Review articles | Prescribing information | Published article | Published articles Abstracts Case reports Review articles Package insert
Number of abstracts cited[years] | - | 1 [2000] | 8 [2000–2001] | - | 0 | 9 [2000–2001]
Number of published articles cited [years] | - | 1 [2001] | 4 (+6 non-cited) [1999–2001] | - | 1 [2003] | 15 (+4 reviews) [1999–2005]
Date of last update | 12/8/2005 | 7/7/2004 | 2006 | 2005 | 12/19/2005 | 12/5/2005

a There is uniform NCCN consensus, based on lower level evidence including clinical experience, that the recommendation is appropriate.

b 12 abstracts and articles cited; 6 additional articles included in the reference list.

c For CLL-specific adverse effect.

d Not including Insert

Studies cited in compendia versus studies identified in EPC review. Only DRUGDEX and USP-DI provided an extensive list of references, which included primary peer-reviewed articles, abstracts, case reports, review articles, and the package insert for rituximab. DRUGDEX includes 18 references relevant to the agent’s use in CLL but discusses its use from only two citations and toxicities from two other citations. USP-DI includes seven of the 33 studies found in the EPC review that were published between 1999 and 2005. Several publications that did not meet the EPC eligibility criteria were referenced, including package inserts, review articles, and a book update. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 13c.

Table 13c Articles cited by compendia vs. articles identified by EPC – rituximab for chronic lymphocytic leukemia

Reference | EPC | AHFS- DI | Clin Pharm | DRUGDEX | F & C | NCCN | USP-DI | Notes
Reviewed by compendia: | - | No | Yes | Yes | No | Yes | Yes | -
Phase III
(none)
Phase II
Del Poeta, 2005^313^ | x
Khouri, 2004^315^ | x
Tsiara, 2004^316^ | x
Byrd, 2003^311^ | x | | | | | x | x
Hainsworth, 2003^317^ | x
Tothova, 2003^312^ | x
Tsimberidou, 2003^318^ | x
Itala, 2002^319^ | x | | | *
Schulz, 2002^320^ | x | | | | | | x
Huhn, 2001^321^ | x | | | * | | | x
Hainsworth, 2000^322^ | x
Ladetto, 2000^323^ | x | | | * | | | x
Nguyen, 1999^324^ | x | | | | | | x
Phase I/II
Keating, 2005^314^ | x | | | | | | x
Wierda, 2005^325^ | x
Weide, 2004^326^ | x
Savage, 2003^327^ | x
Byrd, 2001^328^ | x | | | x | | | x
Winkler, 1999^329^ | x | | | | | | x
Phase I
Perz, 2002^330^ | x
O’Brien, 2001^331^ | x | | | | | | x
Keating, 2000^332^ | x | | x | x | | | x
Other
Narayan, 2005^333^ | x
Robak, 2005^334^ | x
Watanabe, 2005^335^ | x
Nabhan, 2004^336^ | x
Jilani, 2003^337^ | x
Cohen, 2002^338^ | x
Kanelli, 2001^339^ | x
Seipelt, 2001^340^ | x | | | | | | x
Syrigos, 2001^341^ | | | | | | | x | Review
Weiss, 2001^342^ | | | | * | | | x | Review
Herold, 2000^343^ | x | | | * | | | x
Schulz, 2000^344^ | | | | * | | | x | Not available
Byrd, 1999^345^ | x | | | | | | x
Lim, 1999^346^ | x | | | x | | | x
Yang, 1999^347^ | x | | | x | | | x
No. of Abstracts | 10 | | 1 | 8 | | 0 | 9
Abstract Years | 04-05 | | 01 | 00-01 | | | 00-01

* Non-cited reference.

Recommendations and supporting evidence. DRUGDEX discusses the off-label use of rituximab in its section on CLL. It specifies that the “evidence for efficacy is favorable” for the indicated use. While the compendium indicates rituximab use as a combination therapy in untreated CLL, no mention is made regarding the indicated dose. USP-DI included CLL among its list of cancers for which treatment is “Accepted.” There are no data on stage of disease for rituximab use, nor is any information provided. However, rituximab is indicated for first line treatment in combination therapy as well as for relapsed or refractory indications. Treatment effectiveness is quantified.

NCCN discusses rituximab in its section on CLL and small lymphocytic lymphoma. It is offered as an option with other chemotherapeutic agents for secondary treatment of any stage of CLL/SLL. NCCN grades the recommendation as category 2A: “There is uniform NCCN consensus, based on lower level evidence including clinical experience, that the recommendation is appropriate.”

Clinical Pharmacology evaluates rituximab use for an off-label and post-first line use in CLL. The compendium reported rituximab in monotherapy and combination therapy. The dose and effectiveness of the treatment are quantified.

Summary. Listings of rituximab for CLL in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Four of the six compendia (Clinical Pharmacology, DRUGDEX, NCCN, and USP-DI) discuss rituximab for treatment of CLL.
- Specificity of clinical information: The four compendia that discuss rituximab indicate different types of cancer for which the agent should be used, in addition to the combinations of treatments. Clinical Pharmacology discusses appropriate doses. None of the compendia describes the effects of treatment with rituximab. Only DRUGDEX, USP-DI, and Clinical Pharmacology report response data.
- Evidence rating: DRUGDEX and USP-DI include extensive lists of references, although these are reported only as lists of the available evidence.
- Recommendation statements: DRUGDEX makes a class III recommendation, “treatment is not useful and should be avoided,” for the off-label indication based on the strength of evidence category B. NCCN makes a weak recommendation, “option” and “suggested,” based on lower level evidence. USP-DI and Clinical Pharmacology mention the off-label use through passive discussion using cited references. AHFS-DI and Facts & Comparisons did not describe the off-label use of rituximab in CLL.
- Toxicity: Toxicities related to rituximab are reported in most of the compendia, and four (AHFS-DI, DRUGDEX, Facts & Comparisons, and USP-DI) note toxicities specifically in patients with CLL.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include CLL as an off-label indication for gemcitabine. There is no published Phase III study of rituximab in CLL; thus the compendium adheres to its stated methodology, which emphasizes well-designed, controlled, published studies.
- USP-DI specifies that it includes off-label indications, and it does include CLL as an off-label indication for rituximab. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. It cites several Phase II studies in support of the off-label indication, including five of the 13 Phase II studies identified in the EPC review. The last update was 12/5/05, but some 2003–5 data are not cited.
- DRUGDEX specifies that it includes off-label indications, and it does include CLL as an off-label indication for rituximab. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It cites only studies published before 2003, although the date of the last update was 2006.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it does not include CLL as an off-label indication for rituximab. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite any of the Phase II studies identified in the EPC review. The last update was in 2005, but data from 1999–2005 were not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is no explicit off-label indication for rituximab in CLL as per the guideline. The last update was in 2005, but early 2005 data are not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes CLL as an off-label indication for rituximab. It emphasizes prospective trials, but cites only one Phase I study of rituximab in CLL published in 2000; it fails to cite 13 Phase II, 6 Phase I/II, and 2 other Phase I studies identified in the EPC review. The last update was 7/7/04, but data from 1999–2004 were not cited.

## Erlotinib (Tarceva®) for Head and Neck Cancer

Erlotinib is an inhibitor of human epidermal growth factor receptor tyrosine kinase with therapeutic indications for treatment of locally advanced or metastatic NSCLC after failure of at least one prior chemotherapy regimen. Erlotinib has also been evaluated for treatment of head and neck cancer.

### Systematic Review by EPC

A total of 18 articles and abstracts were identified through the EPC literature search. Of these, three met the EPC inclusion criteria.

Table 14a describes the study types of the included studies and the outcomes reported. Appendix B reports details from each of the three articles and abstracts. The literature includes only a single peer-reviewed study, a Phase II trial in 115 patients that reported tumor response, survival data, and adverse effect data.

Table 14a Study types and outcomes reported – erlotinib for head and neck cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 1 | 115 | 2004 | 1 | 1 | - | - | 1
Phase III | - | - | - | - | - | - | - | -
Phase II | 1 (100%) | 115 (100%) | 2004 | 1 | 1 | - | - | 1
Phase I | - | - | - | - | - | - | - | -
Other | - | - | - | - | - | - | - | -
Abstracts^a^ | 2 | 20 | 2005 | 2 | - | - | 1 | 2

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Not considered further.

Peer-reviewed Phase III trials. No Phase III trials have been published.

Peer-reviewed Phase II trials. Only one study of 115 patients with locally recurrent of metastatic head and neck cancer previously treated with other anti-neoplastic agents has been peer-reviewed. The study reported partial response of four percent and overall survival of 6 months. Adverse effect data were also reported, but quality of life and symptom relief data were not reported.

### Compendia Listings

Treatment indication and toxicities. Table 14b summarizes the compendia’s discussions of the off-label use of erlotinib for treatment of head and neck cancer. Clinical Pharmacology, DRUGDEX, and Facts & Comparisons explicitly stated an off-label indication for the agent. NCCN mentions the development of newer tyrosine kinase inhibitors, including erlotinib, to attenuate the overexpression of epidermal growth factor receptor (EGFR) and/or common ligands that has been observed in greater than 90 percent of squamous cell carcinomas of head and neck cancer. The other compendia, regardless of whether they mentioned head and neck cancer, discussed toxicities, including severity and frequency of adverse effects, and which organs were affected. Only DRUGDEX discussed erlotinib-related toxicities specifically among patients being treated for head and neck cancer.

Table 14b Summary of compendia listings – erlotinib for head and neck cancer

| AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Off-label indication explicitly stated | No | Yes | Yes | Yes | No | No
Sub-category of indication (accepted or acceptance not established) | - | NR | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | NR | - | -
Stage of cancers | - | “Metastatic or recurrent squamous cell carcinoma” | “Head and neck cancer” | NR | -
Method of treatment (first line or other) | - | NR | Other | NR | - | -
Routes of administration | - | Oral | Oral | Oral | - | -
Uses of the agent (monotherapy or combination) | - | Monotherapy | Monotherapy | NR for this indication | - | -
Comparator discussed (placebo, standard treatment, other agents) | - | No | No | NR for this indication | - | -
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | Overall response rate Median progression-free survival Median overall survival | Overall response rate Median overall survival | NR | - | -
Toxicity reporting | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: No Cancer-specific: No Severity: By organ: Frequency: | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for the off-label use | - | Yes | No | No | - | -
Number of evidence citations | - | 1 | 3 | None cited for this indication | - | -
Range of years of citations | - | 2004 | 2001 | - | - | -
Sources of evidence (abstracts/published articles) | - | Published study | Abstracts Published study | - | - | -
Number of abstracts cited [years] | - | 0 | 1 [2000] | - | - | -
Number of published articles cited [years] | - | 1 [2004] | 2 Reviews [2001] | - | - | -
Date of last update | 12/8/2005 | 11/9/2005 | 2006 | 2005 | 12/19/2005 | 11/14/2005

Studies cited in compendia versus studies identified in EPC review. Only Clinical Pharmacology referenced the single peer-reviewed study. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 14c.

Table 14c Articles cited by compendia vs. articles identified by EPC – erlotinib for head and neck cancer

Reference | EPC | AHFS- DI | Clin Pharm | DRUGDEX | F & C | NCCN | USP-DI | Notes
Reviewed by compendia: | - | No | Yes | Yes | Yes | No | No | -
Phase III
(none)
Phase II
Soulieres, 2004^348^ | x | | x
Phase I/II
(none)
Phase I
(none)
Other
Adjei, 2001^349^ | | | | x | | | | Not MEDLINE
Ciardiello, 2001^350^ | | | | x | | | | Review
No. of Abstracts | 2 | | 0 | 1 | 0
Abstract Years | 04-05 | | | 00

Recommendations and supporting evidence. Clinical Pharmacology included evaluation of erlotinib for treatment of head and neck cancer. The compendium referenced the single peer-reviewed study and stated that there is an indication for the treatment of head and neck cancer, specifically metastatic or recurrent squamous cell carcinoma. The dose used in the study was cited. DRUGDEX included evaluation of erlotinib for treatment of head and neck cancer. The dose used in one review is cited. Facts & Comparisons did not include any citation relevant to this indication.

Summary. Listings of erlotinib for head and neck cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Three of the six compendia (Clinical Pharmacology, DRUGDEX, and Facts & Comparisons) discuss erlotinib for treatment of head and neck cancer.
- Specificity of clinical information: Clinical Pharmacology describes the cancer indication as “head and neck cancer, specifically metastatic or recurrent squamous cell carcinoma,” with reference to the single peer-reviewed study. DRUGDEX references one abstract and one review and describes the off-label indication as for the treatment of head and neck cancer.
- Evidence rating: Only DRUGDEX provides an explicit evidence rating for the off-label use of erlotinib for head and neck cancer. It assigns the evidence the rating category IIb and also notes that the evidence for efficacy is inconclusive.
- Recommendation statements: Clinical Pharmacology mentions the off-label use through passive discussion using cited references. DRUGDEX makes class III recommendation, “treatment is not useful and should be avoided.”
- Toxicity: Toxicities related to erlotinib are reported in most of the compendia, but only DRUGDEX notes toxicities specifically in patients with head and neck cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include head and neck cancer as an off-label indication for erlotinib. There is no published Phase III study of erlotinib in head and neck cancer; thus the compendium adheres to its stated methodology, which emphasizes well-designed, controlled, published studies.
- USP-DI does not include head and neck cancer as an off-label indication for erlotinib. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. The last update was 11/14/05, but the single Phase II study from 2004 that was identified in the EPC review is not cited.
- DRUGDEX specifies that it includes off-label indications, and it does include head and neck cancer as an off-label indication for erlotinib. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It does not cite the Phase II study identified in the EPC review. The date of the last update was 2006, but 2004 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it includes head and neck cancer as an off-label indication for erlotinib. It emphasizes Phase II, III, and IV studies with over 30 subjects, but does not cite the Phase II study (2004) identified in the EPC review. The date of the last update is not stated, but 2004 data are not cited.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is no off-label indication for erlotinib in head and neck cancer as per the guideline. The last update was 12/19/05, but the 2004 Phase II study is not cited.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes head and neck cancer as an off-label indication for erlotinib. It emphasizes prospective trials, and includes the Phase II trial published in 2004.

## Erlotinib (Tarceva®) for Pancreatic Cancer

As stated above, erlotinib is an inhibitor of human epidermal growth factor receptor tyrosine kinase with therapeutic indications for treatment of locally advanced or metastatic NSCLC after failure of at least one prior chemotherapy regimen. Erlotinib has also been evaluated for treatment of pancreatic cancer.

### Systematic Review by EPC

A total of 22 articles and abstracts were identified through the EPC literature search. Of these, 5 met the EPC inclusion criteria.

Table 15a describes the study types of the included studies and the outcomes reported. The literature includes only a single peer-reviewed study, a Phase I trial in 17 patients which reported tumor response, survival data, and adverse effect data.

Table 15a Study types and outcomes reported – erlotinib for pancreatic cancer

Study type | No. of studies | No. of subjects | Publication years | Outcomes Reported
Study type | No. of studies | No. of subjects | Publication years | TR | Survival | QoL | Sx | AEs
Peer-reviewed studies (total) | 1 | 17 | 2005 | 1 | 1 | - | - | 1
Phase III | - | - | - | - | - | - | - | -
Phase II | - | - | - | - | - | - | - | -
Phase I | 1 (100%) | 17 (100%) | 2005 | 1 | 1 | - | - | 1
Other | - | - | - | - | - | - | - | -
Abstracts^a^ | 4 | 620^b^ | 2004–5 | 1 | 2 | - | - | 4

Abbreviations: AEs = adverse effects; No. = number; QoL = quality of life; Sx = symptoms; TR = tumor response.

a Not considered further.

b Includes subjects who received placebo.

Peer-reviewed Phase III trials. No Phase III trials have been published.

Peer-reviewed Phase II trials. No Phase II trials have been published.

Peer-reviewed Phase I trials. Only one study of 17 patients with pancreatic cancer previously treated with other anti-neoplastic agents has been peer-reviewed. The study reported partial response of 35 percent and a 14 month median survival. Adverse effect data were also reported, but quality of life and symptom relief data were not reported.

### Compendia Listings

Treatment indication and toxicities. Table 15b summarizes the compendia’s discussions of the off-label use of erlotinib for treatment of pancreatic cancer. Only DRUGDEX, USP-DI, and Clinical Pharmacology explicitly stated an off-label indication for the agent. NCCN discussed the Phase III trial data (referencing a review article), but did not include erlotinib in any of its algorithms for treatment of pancreatic cancer. All other compendia, regardless of whether they discussed pancreatic cancer, discussed toxicities, including severity and frequency of adverse effects, and which organs were affected. Only Clinical Pharmacology discussed erlotinib-related toxicities specifically among patients being treated for pancreatic cancer.

Table 15b Summary of compendia listings – erlotinib for pancreatic cancer

| AHFS-DI | Clinical Pharmacology | DRUGDEX | Facts & Comparisons | NCCN | USP-DI
Off-label indication explicitly stated | No | Unclear a | Yes | No | No (but a trial is discussed) | Unclear b
Sub-category of indication (accepted or acceptance not established) | - | NR | Efficacy: Adult, Evidence is inconclusive Recommendation: Adult, Class III Strength of Evidence: Adult, Category B | - | Not discussed | Accepted
Stage of cancers | - | “Locally advanced, unresectable or metastatic” | “Carcinoma of pancreas” | - | “Advanced or metastatic” | “Locally advanced, unresectable or metastatic”
Method of treatment (first line or other) | - | First line | First line | - | NR | First line
Routes of administration | - | Oral | Oral | - | NR | Oral
Uses of the agent (monotherapy or combination) | - | Combination | Combination | - | Combination | Combination
Comparator discussed (placebo, standard treatment, other agents) | - | No | Yes (gemcitabine alone) | - | Yes (gemcitabine alone) | No
Outcomes mentioned for the off-label use (survival, tumor response, other) | - | NR | Overall survival | - | Median survival 1-year survival | NR
Toxicity reporting | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: Yes Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes | Overall: No Cancer-specific: No Severity: By organ: Frequency: | Overall: Yes Cancer-specific: No Severity: Yes By organ: Yes Frequency: Yes
Dose indicated for off-label use | - | Yes | No | - | No | Yes
Number of evidence citations | - | (1 c) | 1 | - | 1 | 1
Range of years of citations | - | NR | 2005 | - | 2004 | 2005
Sources of evidence (abstracts/published articles) | - | 0 | Abstract | - | Review | Product Information
Number of abstracts cited [years] | - | 0 | 1 [2005] | - | 0 | 0
Number of published articles cited [years] | - | 0 | 0 | - | - | 0
Date of last update | 12/8/2005 | 11/9/2005 | 2006 | 2005 | 6/28/2005 | 11/14/2005

a The dagger sign was not used for the indication

b The brackets were not used for this indication

c One study of 259 patients discussed regarding adverse effects for erlotinib use with gemcitabine, but reference was not provided. No studies cited for effect.

Studies cited in compendia versus studies identified in EPC review. No compendium referenced any primary peer-reviewed articles or abstracts. A comparison of references identified in the EPC review versus those cited by the compendia is presented in Table 15c.

Table 15c Articles cited by compendia vs. articles identified by EPC – erlotinib for pancreatic cancer

Reference | EPC | AHFS- DI | Clin Pharm | DRUGDEX | F & C | NCCN | USP-DI | Notes
Reviewed by compendia: | - | No | Yes | Yes | No | Yes | Yes | -
Phase III
(none)
Phase II
(none)
Phase I/II
(none)
Phase I
Iannitti, 2005^351^ | x
Other
McBride, 2004^352^ | | | | | | x | | Review
Unknown | | | a
No. of Abstracts | 4 | | | 1
Abstract Years | 2004–05 | | | 2005

a Discussed a study of 259 subjects, but did not cite a reference.

Recommendations and supporting evidence. Clinical Pharmacology states that there is an indication for erlotinib for the first-line treatment of locally advanced, unresectable, or metastatic pancreatic cancer in combination with gemcitabine. A specific dose is listed, with a reference to the compendium’s gemcitabine monograph. Under the section on adverse reactions, there is a discussion of a study of 259 patients with pancreatic cancer who received erlotinib 100 mg with gemcitabine, but no reference is cited.

DRUGDEX notes the off-label indication for erlotinib for the first line treatment of locally advanced, metastatic pancreatic cancer in combination with gemcitabine. The compendium cites one abstract, and the dose used in the study is mentioned. The effectiveness of the treatment is described as “evidence is inconclusive.”

As noted above, NCCN discussed the Phase III trial data, but did not include erlotinib in any of its algorithms for treatment of pancreatic cancer.

USP-DI includes pancreatic cancer in its list of cancers for which treatment is “Accepted” when used in combination with gemcitabine for first line treatment of patients with locally advanced, unresectable, or metastatic pancreatic cancer. It references the “Product Information” for this information. Referencing the same source, the compendium recommends a specific dose. The effectiveness of the treatment is not discussed.

Summary. Listings of erlotinib for pancreatic cancer in the compendia reviewed here may be summarized as follows:

- Inclusion of off-label indication: Three of the six compendia (Clinical Pharmacology, DRUGDEX and USP-DI) discuss erlotinib for treatment of pancreatic cancer.
- Specificity of clinical information: Clinical Pharmacology and USP-DI both recommend the same dose of erlotinib for pancreatic cancer, to be used in combination with gemcitabine. NCCN discusses erlotinib, but without including it in its algorithms for treatment of pancreatic cancer.
- Evidence rating: Clinical Pharmacology, DRUGDEX, and USP-DI all include erlotinib for the treatment for pancreatic cancer without citing available, peer-reviewed references. Only DRUGDEX provides an explicit evidence rating for the off-label indication of erlotinib for pancreatic cancer (“evidence is inconclusive”).
- Recommendation statements: Clinical Pharmacology mentions the use through passive discussion using cited references. DRUGDEX makes class III recommendation, “treatment is not useful and should be avoided.”
- Toxicity: Toxicities related to erlotinib are reported in most of the compendia, but only Clinical Pharmacology notes toxicities specifically in patients with pancreatic cancer.

### Analysis of Compendia Listings vs. Stated Methodologies

Comparing the compendia listings with their self-described methodologies for dealing with off-label indications, we find that the methodologies and actual practice diverge, predominantly due to subjective assessments of the value and volume of the data, subjective assessments of current practice, and omission of recent citations. Results may be summarized as follows:

- AHFS-DI specifies that it includes off-label indications when they are supported by evidence and current practice; it does not include head and neck cancer as an off-label indication for erlotinib. It emphasizes well-designed, controlled, published studies. No such studies were identified in the EPC review.
- USP-DI discusses the role of erlotinib in pancreatic cancer, even though it does not explicitly state erlotinib as an off-label indication. In its methodology it emphasizes Phase III and IV studies, with lower level evidence to be included at the discretion of its staff. No Phase III or IV studies were identified in the EPC review.
- DRUGDEX specifies that it includes off-label indications, and it does include pancreatic cancer as an off-label indication for erlotinib. In its methodology it emphasizes a comprehensive review of available evidence, including case reports. It does not cite the single Phase I study identified in the EPC review. The date of the last update was 2006, but 2005 data are not cited.
- Facts & Comparisons specifies that it includes off-label indications when legitimate and appropriate; it does not include pancreatic cancer as an off-label indication for erlotinib. It emphasizes Phase II, III, and IV studies with over 30 subjects; no such studies were identified in the EPC review.
- NCCN specifies that it includes off-label indications when they are included in its clinical practice guidelines. There is an off-label indication for erlotinib in pancreatic cancer as per the guideline. The single Phase I study (2005) identified in the EPC review is not cited. The last update was 6/28/05.
- Clinical Pharmacology specifies that it includes an off-label indication when it is in current clinical practice and the dose is available; it includes pancreatic cancer as an off-label indication for erlotinib. It emphasizes prospective trials, but does not cite the Phase I trial published in 2005. The date of the last update was 11/9/05, but 2005 data are not cited.