# Methods

The project was divided into four distinct components: (1) a description of the methods used by the compendia; (2) a comprehensive search by the EPCs for studies on the 14 selected off-label indications; (3) a description of the compendia listings and evidence cited for the same 14 off-label indications; and (4) an analysis of the compendia’s listings in relation to their stated methodologies.

## Description of the Methods Used by the Compendia

In theory, compendia are like reports of systematic reviews in that they identify, appraise, and synthesize a body of evidence. It is useful to evaluate to what extent compendia describe their methods for search, selection, and summarization of evidence, and to what extent they follow their stated methods. Compendia are also like guidelines in that they endorse certain drugs for particular clinical indications; this is particularly evident in the case of off-label indications. It is useful to evaluate to what extent compendia describe their methods for developing recommendations, and to what extent they meet standards for clinical practice guidelines. The QUOROM consensus statement12 and the AGREE instrument13 – which were originally developed for assessing the reporting quality of reports of meta-analyses and clinical practice guidelines, respectively – provide reasonable frameworks for these evaluations of drug compendia.

We reviewed evaluation criteria in the QUOROM statement and the AGREE instrument and eliminated duplicate and non-applicable items. The remaining items were used to guide our evaluation of published compendia methods, as well as interviews with compendia editors.

We did not use explicit scoring rules as described in the AGREE instrument, nor did we report explicit “yes” or “no” decisions on QUOROM items. Rather, these documents were used as conceptual models to organize our inquiry into the methods used by drug compendia.

We planned a five-step process to gather information from the compendia as follows:

- [underlined: Step 1]: Abstract descriptive information about each compendium based on printed or other publicly available information into a table using the conceptual framework described above.
- [underlined: Step 2]: Send the table completed in Step 1 to the publisher of each compendium and schedule an interview with appropriate personnel. In each case, we scheduled 1-hour telephone interviews with the most senior editor and any additional staff they recommended.
- [underlined: Step 3]: Interview compendium staff to supplement published information about methods used for evidence synthesis and decisionmaking. We conducted interviews with at least two members of our research team present. We prepared minutes from the calls based on written notes taken by each of the participants. Interviews were not audio recorded.
- [underlined: Step 4]: Revise table to include additional information gained on interview and send revised table to compendium staff to get confirmation or alternative views.
- [underlined: Step 5]: Combine the descriptive information on all six compendia compiled in Steps 1–4 into a series of tables to allow comparison across compendia on various topics.

During the conduct of the study, we decided to eliminate the first review by compendia editors and thus did not send a draft of the table before our telephone interviews. After the interviews, when we sent the editor a draft table summarizing the compendium’s methods, we blinded them to data from the other compendia, so that each editor saw only data about his or her own publication.

Ultimately, we organized the information from our inquiry for brevity and clarity, with special attention to the domains in which the compendia differ.

## EPC Review of Published Studies on the 14 Off-Label Indications

### Literature Search

We searched MEDLINE and MEDLINE In-Process & Other Non-indexed Citations (formerly called PreMEDLINE) to identify human studies published in English that investigated the targeted agent-cancer combinations and reported outcomes of interest. We also searched the American Society of Clinical Oncology (ASCO) annual meeting abstracts for the years 2004 and 2005 for recently reported but as yet unpublished studies. The MEDLINE search strategies used are provided in Appendix A.

### Study Selection

We included all study designs including clinical trials (Phase I, Phase I/II, Phase III, or Phase IV), case reports, and retrospective case series that reported any of the following outcomes: tumor response, survival, quality of life, symptomatic improvement, or adverse effects. We excluded review articles, studies that described only predictors of response, pharmacokinetic studies, and animal or in vitro studies.

### Data Abstraction

We retrieved and reviewed published abstracts and/or full-text articles on eligible studies for each of the agent-cancer combinations. Key data were abstracted into evidence tables (Appendix B). One investigator abstracted the data, and a second verified the abstraction. The abstracted data included: author; year of publication; dose of agent for the indicated use; co-intervention(s); comparator(s); brief description of the cancer stage; indicated line of treatment (first or greater); study design; and outcomes (tumor response rate; survival rates; duration data for survival and progression-free survival; QoL; symptoms; and adverse effects reporting by severity, by organ and frequency). We recorded quantitative data on the tumor response and survival outcomes, and p-values related to comparisons with baseline or comparator treatments, but recorded only qualitative data on QoL, symptoms, and adverse effects (whether reported by severity, by organ system, or by frequency). For full-text articles, we attempted to obtain the required data from the study abstract wherever possible, but retrieved the full text when the abstract provided insufficient information.

### Synthesis

To facilitate comparisons, for each of the agent-cancer combinations we created summary tables that list the number of articles identified by study design, describe the outcomes reported, and synthesize data for key outcomes, focusing on the efficacy outcomes of tumor response and survival.

## Description of Compendia Listings and Evidence Cited for the 14 Agent-Cancer Combinations

We evaluated all versions of the compendia available to us (print and electronic), but recorded data from the most current and complete versions; in every case, this was an electronic version. We abstracted data from each of the six compendia for each of the 14 agent-cancer combinations. Data abstracted included: whether the off-label indication was explicitly stated; how the indication was graded; comments on further refinement regarding the stage of cancer; method of treatment; route of administration; and use of mono- or combination therapy. We recorded outcomes mentioned specifically in connection with the off-label use, as well as toxicity data. We also recorded the presence of citations to evidence on the off-label indication; the number, identity, and years of the citations; and the date of the most recent update of the compendium monograph or entry.

## Analysis of Compendia Listings in Relation to their Stated Methodologies

For each of the 14 agent-cancer combinations, we constructed a matrix to show all the articles, abstracts, and other publications identified from any source (whether from the EPC review or from the compendia citations), with an indication of which compendia cited each publication. For this purpose, publications were stratified by study design, and abstracts were noted separately.

We evaluated each compendium listing in relation to the known literature, identified as described above, and in relation to the compendium’s stated methodology as follows:

1. Given the compendium’s stated criteria for selecting evidence (study design, methodological quality, etc.), was all the relevant evidence meeting those criteria cited?
2. Given the date of the most recent update of the compendium listing, was all eligible and available evidence cited?
3. Given the eligible, available evidence, was the compendium’s decision on listing (listing versus no listing) consistent with our own assessment?