# Introduction

The topic of this assessment is the evaluation of drug compendia for the purpose of informing the Centers for Medicare & Medicaid Services (CMS) on decisions about coverage of off-label uses of drugs and biologics in anticancer treatment. This coverage is dictated by Section 1861(t)(2)(B) of the Social Security Act, which describes the reliance upon recommendations in compendia, specifically the AMA Drug Evaluations (AMA-DE; no longer in existence), American Hospital Formulary Service Drug Information (AHFS-DI1), and United States Pharmacopeia Drug Information (USP-DI2).

Rapidly advancing medical technologies, drugs, and biological agents can improve survival and quality of life (QoL) of patients. Physicians and researchers often discover uses of drugs other than those for which they have been approved by the U.S. Food and Drug Administration (FDA). The term “off-label” can mean many things: “[U]sing an approved drug to treat a disease that is not indicated on its label, but is closely related to an indicated disease; treating unrelated, unindicated diseases; and treating the indicated disease but varying from the indicated dosage, regimen, or patient population may all be considered off-label use.”3 The medical treatment in oncology practice is complex, with uncertain patient outcomes. According to a study by the U.S. General Accounting Office (GAO) in 1991, the off-label use of anticancer drugs was as high as 33 percent of all anticancer drug prescriptions. Today 50 to 75 percent of all uses of anticancer therapy are off-label according to the National Comprehensive Cancer Network (NCCN) estimates.4 Cancers are life-threatening illnesses, and advances in anticancer drug research can outpace approval rates by the FDA; this can result in an increased use of off-label drugs in oncology practice. The increased off-label use of drugs in cancer therapy may be due to several other reasons as well: the lack of, or failure of, standard treatments; lack of FDA approved treatments for rare cancers; and lack of an established proven therapy in the face of terminal illness.

Listings of off-label indications in drug compendia affect not only reimbursement decisions, but also utilization. Several studies have suggested that oncologists alter their preferred treatment due to reimbursement restrictions and costs of certain drugs.5, 6 Laetz6 published the national survey conducted by GAO among oncologists on the prevalence of off-label use, the extent of reimbursement denials, and the effect of reimbursement denials on the treatment of cancer patients. As many as 40 percent of oncologists reported altering their preferred therapies due to cost or other reimbursement barriers. More recently, Dornbusch5 conducted a survey among 310 oncologists after publication of Phase III clinical trial data evaluating the use of bevacizumab in non-small cell lung carcinoma (NSCLC). More than 50 percent of the respondents said they planned to use off-label bevacizumab in NSCLC as soon as reimbursement is secure.

In order to inform potential future coverage determinations, CMS has commissioned a technology assessment from the Agency for Healthcare Research and Quality (AHRQ) to summarize the process by which anticancer drugs are added to various compendia, as well as the evidence collection methodology for listed drugs and their indicated uses. The Duke Evidence-based Practice Center (Duke EPC) and the Tufts-New England Medical Center EPC (Tufts-NEMC EPC) were asked by AHRQ to prepare this report and present at a Medicare Coverage Advisory Committee (MCAC) meeting on March 30, 2006.

## Scope and Key Questions

The key questions addressed in this report are:

1. How do the methods used to develop compendia listings compare to methods used to develop published guidelines, systematic reviews, and narrative reviews? How do they compare to the publication criteria of journals?
2. Describe the compendia on the following:
  a. Breadth of listings
  b. Speed of throughput from application to listing
  c. Use of pre-specified, published criteria for weighing evidence
  d. Use of pre-specified, published process for making recommendations
  e. Level of public transparency in the process of evaluating therapies
  f. Public notification of reviewers’ and committee members’ conflict(s) of interest, including institutional funding sources
  g. Public notification of all funding sources of the compendium and its parent and sibling organization(s), including unrestricted grants and gifts
3. For chosen drugs/biologics and their off-label indications, evaluate the compendia on the following:
  a. Level of detail of the evidence reviewed
  b. Any recommendations that are made (i.e., explicit “Not Recommended” listings or explicit “Equivocal” listings when evidence is equivocal)
  c. Silence, i.e. no listing, when evidence is equivocal
  d. Presence of bias (i.e., “Recommended” when evidence is equivocal or “Not Recommended” when evidence is equivocal)
4. Is there an analysis of potential harms and potential benefits in the assessment of biologics and chemotherapeutic agents included in the compendia? If yes, what components are used, and how are they quantified?
5. Which compendia have listings on the off-label uses of drugs/biologics chosen for this report? If these drugs/biologics and specified off-label indications are included in compendia:
  a. How do each compendium’s listings compare with its own stated methods?
  b. How do each compendium’s listings compare to those of other compendia for the same drugs/biologics and off-label indications?
  c. How do they compare to the EPC’s own review of the evidence?
6. Do the two current compendia in use by Medicare for the determination of off-label uses of anticancer drugs and biologics in anticancer treatment, the AHFS and the USP-DI, adhere to their stated criteria and processes in making recommendations?

The overall goal of this report is to evaluate a selected set of documents that may be considered to be drug compendia using certain pre-specified criteria to determine to what extent these compendia use evidence-based approaches in their collection, review, and reporting of the literature. This report does not address or make any assessments of the overall quality or usefulness of these compendia for the purposes of clinician education, assistance with patient management, or prescriber decisionmaking.

The following compendia are evaluated:

- American Hospital Formulary Service- Drug Information (AHFS-DI)1
- United States Pharmacopeia- Drug Information (USP-DI; available through Thomson MICROMEDEX)2
- DRUGDEX Information System (also available through Thomson MICROMEDEX)2, 7
- Facts & Comparisons8
- National Comprehensive Cancer Network Drugs and Biologics Compendium (NCCN)9
- Clinical Pharmacology10

This list does not include all documents that may be considered either to be or to be similar to drug compendia. CMS, AHRQ, and the two EPCs agreed on this list as the most relevant for the purposes of this review. For some of these compendia, several different versions or related documents may exist. When necessary, we chose the version that was both most accessible and had the most detailed information.

Given the large number of anticancer agents and cancers, it was not be possible to evaluate all possible agent-cancer combinations for off-label indications. With input from CMS and AHRQ, the EPCs identified several combinations for evaluation. These combinations were selected to reflect newer and older agents, common and rare cancers, and both biologics and drugs.

Fourteen agent-cancer combinations were evaluated:

- Bevacizumab (Avastin®) for breast and lung cancer (approved by the FDA in February 2004 for colorectal cancer);
- Oxaliplatin (Eloxatin®) for breast and lung cancer (approved by the FDA in 2004 for colorectal cancer);
- Irinotecan (Camptosar®) for breast cancer (approved by the FDA in 1998 for colorectal cancer);
- Docetaxel (Taxotere®) for esophageal, gastric, and ovarian cancers (approved by the FDA in 1999 for locally advanced or metastatic non-small cell lung cancer [NSCLC]);
- Gemcitabine (Gemzar®) for biliary tract, bladder, and ovarian cancers (approved by the FDA in 1996 for pancreatic cancer);
- Rituximab (Rituxan®) for chronic lymphocytic leukemia (CLL; approved by the FDA in 1997 for non-Hodgkin’s lymphoma); and
- Erlotinib (Tarceva®) for head and neck, and pancreatic cancers (approved by the FDA in 2004 for NSCLC).

Among all new cancer cases in women, breast cancer is estimated to comprise 32 percent and ovarian cancer 2.9 percent. Among all new cancers in both men and women, the rate of lung cancer is 12 percent; esophageal is 1 percent; gastric is 2 percent; bladder cancer is 4 percent; head and neck cancer is 3 percent; pancreatic cancer is 2 percent; chronic lymphocytic leukemia is 0.7 percent; and biliary tract cancer is 0.6 percent.11

The Duke EPC and the Tufts-NEMC EPC jointly produced this report. The Duke EPC addressed key questions 1 and 2 concerning the methods of the compendia. Both EPCs addressed the remaining questions, which dealt with the reporting of information by the compendia and the assessment of the availability of literature evidence for the agent-cancer combinations selected for evaluation in this report. For the literature review, common methods were used to identify potentially relevant studies, abstract data, and report results wherever feasible to enhance the consistency of this report. The Introduction, Methods, and Discussion sections of the report were written jointly by the two EPCs, while the various Results sections represent non-overlapping independent work of each EPC that shared the same methodological approach.