# Discussion

Compendia claim to use evidence-based methods in their evaluation of therapeutic agents. While the compendia describe general approaches to identifying literature, evaluating studies, and formulating recommendations, we noted important discrepancies between a complete and systematic enumeration of relevant supporting clinicals studies and the literature cited in the compendia. Since the first step in a critical appraisal of literature is the systematic search and identification of relevant studies, the problems we have identified in reporting of references indicate a potential problem with the compendia. Cited literature was often neither the most recent nor the most valid in terms of study design. While it may not be necessary for compendia to provide a thorough enumeration of literature considered, the lack of transparency makes it difficult to determine whether omitted references had been identified but excluded (e.g., due to poor quality or lack of relevance) or never identified and considered. This is particularly problematic when compendia do not include a listing for a particular off-label indication, as a discussion of evidence or a rationale for no listing is seldom provided (we refer to this as “silence” on a particular indication). All the compendia are less transparent in their methods than published systematic reviews, or they do not adhere to standards for reporting of systematic reviews.12, 353

Drug compendia are primarily organized according to individual drugs or biologics, or sometimes according to drug classes. They are not organized – as clinical practice guidelines are – according to a clinical presentation or disease for the purpose of disease management. Thus, compendia typically do not provide a comparison between different therapeutic choices for a particular condition. However, some have added indexing by condition (e.g., Facts & Comparisons), and some have made evaluation of therapeutic alternatives a standard part of the editorial process (e.g., AHFS-DI).

We noted important differences between various versions of the same compendium. Most significant were differences between print media editions and electronic media editions. Electronic media editions were typically updated more quickly and contained more information, particularly citations. However, several compendia published multiple electronic media editions, with differences in update schedules and content; this creates the potential for confusion. For example, DRUGDEX, which provides a detailed description of drugs and includes citations, may be confused with a similar product from the same publisher, DrugPoints, which provides only summary information without references. Differences in updates appear to have caused discrepancies between print and electronic editions on listing of non-approved indications.

We also noted important differences between the compendia in their citation of evidence. Each of the editors noted in interviews that they had made, or planned to make, changes in their editorial policies to become more transparent in regard to how evidence was used in their evaluations. However, several characteristics of the compendia may be obstacles to greater transparency:

- Space limitations of the print medium; electronic media have been utilized by several publishers to overcome space limitations and provide citations.
- Purpose-designed to be concise and easy to use; additional detail on evidence may be at odds with this goal.
- Scope of the task of keeping broad listings current; each compendium has mechanisms for prioritizing topics for updates and managing limited staff resources.

Among the 14 agent-cancer combinations we examined, there was a great deal of variability in whether compendia listed a non-approved indication (Table 16). DRUGDEX was the only compendium that discussed all 14 of the agent-cancer combinations evaluated. Only the indications of gemcitabine for bladder and ovarian cancer were discussed by all six compendia. These indications were the only two of the 14 indications we examined that were discussed by AHFS-DI. Clinical Pharmacology, NCCN, and USP-DI each discussed nine of the 14 combinations, though they differed in which combinations were omitted.

Table 16 Discussion of agent-cancer combinations by compendia

| AHFS-DI | Clin Pharm | DRUGDEX | F & C | NCCN | USP-DI | No. of Compendia
Bevacizumab – breast | No | No | Yes | No | Yes | No | 2
Bevacizumab – lung | No | Yes | Yes | Yes | Yes | Yes | 5
Oxaliplatin – breast | No | Yes | Yes | No | No | No | 2
Oxaliplatin – lung | No | No | Yes | No | No | No | 1
Irinotecan – breast | No | No | Yes | No | No | No | 1
Docetaxel – esophageal | No | No | Yes | Yes | Yes | Yes | 4
Docetaxel – gastric | No | Yes | Yes | Yes | Yes | Yes | 5
Docetaxel – ovarian | No | Yes | Yes | Yes | Yes | Yes | 5
Gemcitabine – biliary tract | No | No | Yes | Yes | Yes | Yes | 4
Gemcitabine – bladder | Yes | Yes | Yes | Yes | Yes | Yes | 6
Gemcitabine – ovary | Yes | Yes | Yes | Yes | Yes | Yes | 6
Rituximab – CLL | No | Yes | Yes | No | Yes | Yes | 4
Erlotinib – head & neck | No | Yes | Yes | Yes | No | No | 3
Erlotinib – pancreas | No | Yes | Yes | No | No a | Yes | 3
No. of agent-cancer combinations | 2 | 9 | 14 | 8 | 9 | 9

a But a trial is discussed.

Some patterns emerge by compendium. DRUGDEX more often than the other compendia listed off-label indications, while AHFS-DI did so less often than the other compendia. Since the compendia rarely describe evidence in the absence of a listing, it is impossible to determine the reasons for silence, and thus is difficult to determine with certainty the reasons for the variability.

The compendia differed in the terminology used to state whether agents were indicated for specific cancers. Several of the compendia also used different terminology or approaches for different agent-cancer combinations. Uniquely, NCCN categorized its recommendations by cancer, as opposed to by agent. Also uniquely, NCCN consistently used explicit “Categories of Consensus,” where all recommendations were category 2A (“There is uniform NCCN consensus, based on lower level evidence including clinical experience, that the recommendation is appropriate.”) unless otherwise indicated. USP-DI categorized cancers into those for which use of the agent was “Accepted” or “Acceptance not established.” USP-DI also explicitly indicated whether agents were included in U.S. product labeling. Only for ovarian cancer did USP-DI state that the indication for gemcitabine has an evidence rating of IIID (although this was not defined within the document). AHFS-DI generally does not make explicit recommendations, but instead makes broader comments such as that an agent “is used for” or “is an active agent against” specific cancers. Similarly, Clinical Pharmacology describes several studies for each agent-cancer combination without explicitly stating whether the agent is indicated; although for each agent, it discusses cancers only when use of the agent represents current practice and a dosage regimen has been established and documented. DRUGDEX makes explicit recommendation ratings (class II to III) for each of the 14 agent-cancer off label indications. Facts & Comparisons only categorizes indications as FDA labeled or unlabeled uses for each agent. Examples of the different wording of recommendations and related statements follow:

- AHFS-DI: “Gemcitabine is an active agent that is used alone [3 references] or in combination therapy [2 references] for the treatment of advanced or metastatic bladder cancer….”
- Clinical Pharmacology: “Adults: Doses not established. As a single agent, gemcitabine… was evaluated in patients with recurrent epithelial ovarian cancer. Of the 22 patients treated, 2 complete responses (9.1 percent) … were reported …[1 reference].”
- DRUGDEX: “For the indicated use of gemcitabine in transitional cell carcinoma of bladder … evidence favors efficacy.” “Recommendation: Adult, Class IIb. Strength of Evidence: Adult, Category B.”
- Facts & Comparisons: “Unlabeled uses: Bladder cancer; biliary cancer; … ovarian cancer.”
- NCCN: For gemcitabine and cisplatin for bladder cancer: “This combination is considered a standard first-line choice for most patients. [category 2A" and “For salvage therapy, paclitaxel…, gemcitabine, or ifosfamide is advised depending upon the patient’s current status.”
- USP-DI: Under “Accepted” category: “Rituximab is indicated for the treatment of relapsed/refractory chronic lymphocytic leukemia (CLL) [25 references],” and “Gemcitabine is indicated, alone or in combination with other chemotherapeutic agents, as reasonable medical therapy at some point in the management of patients with advanced or relapsed epithelial ovarian carcinoma (Evidence rating: IIID) [1 reference].”

Facts & Comparisons provided only basic information about whether the agents were indicated, about dosing, administration, contraindications, adverse effects, and drug interactions. The evidence was not discussed or cited. In contrast, USP-DI and DRUGDEX generally provided an extensive set of references, although many of the references were of abstracts or review articles. In general, USP-DI did not attempt to discuss or summarize the evidence, but instead simply provided references after statements such as that the agent is indicated for the cancer; however, the proportion of the available evidence that was cited varied substantially across indications. Both for gemcitabine for biliary cancer and rituximab for CLL approximately half of the studies identified in the EPC review were cited, while for gemcitabine for both bladder and ovarian cancer less than 10 percent of the available evidence was cited. Similarly, AHFS-DI cited fewer than 10 percent of the available studies, but discussed them in greater detail than USP-DI. In at least four of the agent-cancer combinations, several (or a majority) of the citations provided by DRUGDEX were not linked to the text, but were simply included in reference lists. (Our count of these additional references may be an underestimate, since we relied only on the titles in the reference lists to determine potential eligibility.) Clinical Pharmacology and NCCN generally referenced at most one or two studies, focusing on Phase III or other specific trials.

Among the 14 examples, there was a great deal of variability in how up-to-date the cited literature was between topics and between compendia. For example, there were three important Phase III studies of bevacizumab published last year, two in breast cancer and one in lung cancer. Of these, one was published in full-text form (breast cancer), and the others were presented as abstracts only. The fully published breast cancer trial (bevacizumab combined with capecitabine) showed improvement in tumor response, but not for progression-free survival (the primary end-point) or overall survival. The Phase III trial abstract (bevacizumab combined with paclitaxel) reported an improvement in tumor response, progression-free, and overall survival. None of the compendia cited either study, including the two compendia that listed this non-approved indication (DRUGDEX and NCCN). However, for lung cancer, five of the compendia listed an off-label indication for bevacizumab, and three of the five cite the recent Phase III trial. This Phase III trial was presented only in abstract form as well. Bevacizumab combined with carboplatin and paclitaxel significantly improved tumor response and progression-free and overall survival. It may be that the lung cancer abstract was identified because it was presented at the ASCO 2005 meeting, a venue that receives close scrutiny and from which many citations are listed. However, it is unclear why the breast cancer trials, one published in full in early 2005 and the other also presented at ASCO, were missed by all of the compendia studied. Similarly, a Phase III trial for gemcitabine for bladder cancer was not mentioned in three of six compendia despite being published over 5 years ago. Finally, we note that often when abstracts are cited as evidence supporting a non-labeled indication, these citations are infrequently revised to reflect subsequent publication of the same study in full.

It was difficult for us to ascertain the reason for cases in which the cited evidence did not seem current; revision dates for drug monographs are not always provided, and even when they are provided, they do not clearly indicate what content was revised. For example, a recent revision date might reflect a change in adverse effect information, but off-label indications may not have been reviewed, or the literature search updated.

The primary area of uniformity across compendia, with the exception of NCCN, is in discussions about adverse effects. The compendia mostly fully report on adverse effects and toxicities for each agent, generally as provided by packaging inserts. NCCN, which divided its discussions by cancer instead of by agent, does not discuss adverse effects. However, the compendia varied by whether they discussed cancer-specific toxicities. DRUGDEX discussed cancer specific toxicities from articles cited for all of the agent-cancer combinations. AHFS-DI discussed toxicities of gemcitabine when used for bladder cancer and of rituximab when used for CLL (although CLL was not discussed as an indication for rituximab), but not toxicities of other agents used for specific other cancers. Likewise Clinical Pharmacology discussed cancer-specific toxicities for only three of the 14 agent-cancer combinations (gemcitabine-bladder, gemcitabine ovary, and erlotinib-pancreas), and Facts & Comparisons discusses rituximab-related deaths in CLL.

Our assessment of the off-label indications for anticancer agents listed by various compendia had several limitations; we will describe the three most important. First, we assessed only a limited number of combinations of agents and cancers. While we attempted to select representative examples (older and newer agents, rare and common cancers, well-studied and poorly studied areas), nevertheless there are many more indications and drugs that we did not evaluate. However, given that variability is one of the key findings we observed among the 14 examples we evaluated, additional examples would be unlikely to lead to a different conclusion.

Second, although we probably identified most available published data on the 14 example indications, we did not thoroughly evaluate the studies in terms of the magnitude of effects and the methodological quality of the studies. In particular, we did not specify a definition a priori for equivocal evidence or identify among the examples situations for which we believed the evidence to be equivocal. Our approach of stratifying studies by research design adjusts in a gross way for study quality; however, a more detailed evaluation of study quality might lead to modified conclusions. While the compendia do perform a careful assessment of the studies they identify, they cite few of the available studies. We were also not able to ascertain whether the relatively small number of available studies that were referenced by the compendia accurately reflect the amount of evidence on which the recommendations and discussions were based; however, differences in interpretation of the evidence are more likely to reflect what evidence was considered rather than how the evidence was evaluated.

Finally, we evaluated only the most current listings; each of the compendia is an evolving resource that changes as new information becomes available. Off-label listings may be added or removed over time, as new drugs or new evidence becomes available and practice patterns change. Our methods did not permit us to ascertain whether silence for certain indications reflected a withdrawn off-label indication listing, or one that had never been listed.

In conclusion, our assessment found little agreement between our independent identification of evidence on 14 example off-label indications and the evidence cited in drug compendia. Furthermore, the compendia we examined were discordant in which combinations of agents and cancers were discussed, how they stated whether an agent is indicated for a specific cancer, the level of detail regarding its use, and how the evidence was discussed and referenced. In general, a small percentage of the available evidence was explicitly cited. There was little agreement in the evidence regarding efficacy cited between drug compendia, and although adverse effects are generally fully described, the compendia are discordant on whether they discuss adverse effects among patients with specific cancers. When compendia did not include an off-label indication, it was impossible for us to ascertain whether silence reflected a conscious editorial decision after evaluation of available evidence, or a case where available evidence was not identified and evaluated.