# Search Strategies

The appendix is not available from the publisher at this time.