# References

1 AHFS-DI® (AHFS - Drug Information). Bethesda, MD. American Society of Health-System Pharmacists. 2006.
2 Klasco R. USP DI® Drug Information for the Health Care Professional. 2006;I.
3 Christopher W. Off-Label Drug Prescription: Filling the Regulatory Vacuum. Food and Drug Law Journal. 1993;48:247-262.
4 Soares M. “Off-Label” Indications for Oncology Drug Use and Drug Compendia: History and Current Status. Journal of Oncology Practice. 2005;1(3):102-105. [pmid: 20871690].
5 Dornbusch D, Allegra C, Willey J, et al. How do U.S. medical oncologists learn and apply new clinical trials information from press releases in nonmedical media? A case study based on ECOG 4599. Oncologist. 2006;11(1):31-38. [pmid: 16401711].
6 Laetz T, Silberman G. Reimbursement policies constrain the practice of oncology. [erratum appears in JAMA 1992 Jun 24;267(24):3287]. JAMA. 1991;266(21):2996-2999. [pmid: 1820471].
7 Klasco RE. DRUGDEX® System. 2006.
8 Facts & Comparisons. Drug Facts and Comparisons. 2006. Drug identifier: the premier tool for the correct identification of drugs. St. Louis, MO. Wolters Kluwer Health, Inc. 2006.
9 NCCN Drugs & Biologics Compendium®. 2006.
10 Gold Standard I. Clinical Pharmacology®. 2006.
11 Jemal A, Siegel R, Ward E, et al. Cancer statistics. 2006. CA Cancer J Clin. 2006;56(2):106-130. [pmid: 16514137].
12 Moher D, Cook D, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the Quorom Statement. Lancet. 1999;354:1896-1900. [pmid: 10584742].
13 AGREE Collaboration. Development and validation of an international appraisal instrument for assessing the quality of clinical practice guidelines: the AGREE project. Quality and Safety in Health Care. 2003;12(1):18-23. [pmid: 12571340].
14 Miller K, Wang M, Gralow J, et al. E2100: A randomized phase III trial of paclitaxel versus paclitaxel plus bevacizumab as first-line therapy for locally recurrent or metastatic breast cancer. Presented at the ASCO Annual Meeting. 2005.
15 Miller KD, Chap LI, Holmes FA, et al. Randomized phase III trial of capecitabine compared with bevacizumab plus capecitabine in patients with previously treated metastatic breast cancer. Journal of Clinical Oncology. 2005;23(4):792-799. [pmid: 15681523].
16 Miller KD. E2100: a phase III trial of paclitaxel versus paclitaxel/bevacizumab for metastatic breast cancer. Clinical Breast Cancer. 2003;3(6):421-422. [pmid: 12636887].
17 Overmoyer B, Silverman P, Leeming R, et al. Phase II trial of neoadjuvant docetaxel with or without bevacizumab in patients with locally advanced breast cancer. presented at 2004 ASCO Annual Meeting. 2004.
18 Rugo H, Dickler M, Scott J, et al. Change in circulating endothelial cells (CEC) and tumor cells (CTC) in patients (pts) receiving bevacizumab and erlotinib for metastatic breast cancer (MBC) predicts stable disease at first evaluation. presented at 2005 ASCO Annual Meeting. 2005.
19 Dickler M, Rugo H, Caravelli J, et al. Phase II trial of erlotinib (OSI-774), an epidermal growth factor receptor (EGFR)-tyrosine kinase inhibitor, and bevacizumab, a recombinant humanized monoclonal antibody to vascular endothelial growth factor (VEGF), in patients (pts) with metastatic breast cancer (MBC). presented at 2004 ASCO Annual Meeting. 2004.
20 Traina T, Dickler M, Caravelli J, et al. A feasibility study of an aromatase inhibitor (AI), letrozole (L) and the antibody to vascular endothelial growth factor (VEGF), bevacizumab (B), in patients (pts) with hormone receptor-positive metastatic breast cancer (MBC). presented at 2005 ASCO Annual Meeting. 2005.
21 Cobleigh MA, Langmuir VK, Sledge GW, et al. A phase I/II dose-escalation trial of bevacizumab in previously treated metastatic breast cancer. Seminars in Oncology. 2003;30(5 Suppl 16):117-124. [pmid: 14613032].
22 Cobleigh M, Miller K, Langmuir V, et al. Phase II dose escalation trial of Avastin (TM) (bevacizumab) in women with previously treated metastatic breast cancer (Abstract #520). Breast Cancer Res Treat. 2001;69(3):301.
23 Denduluri N, Wedam S, Yang S, et al. Effect of bevacizumab and chemotherapy on serum levels of sVCAM-1 in patient with inflammatory and locally advanced breast cancer. presented at 2005 ASCO Annual Meeting. 2005.
24 Skillings J, Johnson D, Miller K, et al. Arterial thromboembolic events (ATEs) in a pooled analysis of 5 randomized, controlled trials (RCTs) of bevacizumab (BV) with chemotherapy. presented at 2005 ASCO Annual Meeting. 2005.
25 Wedam S, Low J, Yang X, et al. A pilot study to evaluate response and angiogenesis after treatment with bevacizumab in patients with inflammatory breast cancer. presented at 2004 ASCO Annual Meeting. 2004.
26 Pegram MD, Reese DM. Combined biological therapy of breast cancer using monoclonal antibodies directed against HER2/neu protein and vascular endothelial growth factor. Seminars in Oncology. 2002;29(3 Suppl 11):29-37. [pmid: 12138395].
27 Herbst RS, Johnson DH, Mininberg E, et al. Phase I/II trial evaluating the anti-vascular endothelial growth factor monoclonal antibody bevacizumab in combination with the HER-1/epidermal growth factor receptor tyrosine kinase inhibitor erlotinib for patients with recurrent non-small-cell lung cancer. Journal of Clinical Oncology. 2005;23(11):2544-2555. [pmid: 15753462].
28 Sandler A, Gray R, Brahmer J, et al. Randomized phase II/III Trial of paclitaxel (P) plus carboplatin (C) with or without bevacizumab (NSC # 704865) in patients with advanced non-squamous non-small cell lung cancer (NSCLC): An Eastern Cooperative Oncology Group (ECOG) Trial - E4599. presented at 2005 ASCO Annual Meeting. 2005.
29 Johnson DH, Fehrenbacher L, Novotny WF, et al. Randomized phase II trial comparing bevacizumab plus carboplatin and paclitaxel with carboplatin and paclitaxel alone in previously untreated locally advanced or metastatic non-small-cell lung cancer. Journal of Clinical Oncology. 2004;22(11):2184-2191. [pmid: 15169807].
30 Raefsky E, Spigel D, Greco F, et al. Irinotecan (I), carboplatin (C), and radiotherapy (RT) followed by bevacizumab (B) in the treatment of limited-stage small cell lung cancer (SCLC): a phase II trial of the Minnie Pearl Cancer Research Network. presented at 2005 ASCO Annual Meeting. 2005.
31 Delaloge S, Tubiana-Hulin M, Wardley A, et al. A multistep randomized phase II/III trial comparing oxaliplatin (OXA)+5 fluorouracil (FU) to vinorelbine (VIN)+FU (FUN) after taxane (T)/anthracycline (A) failure in advanced/metastatic breast cancer (MBC) patients (pts): Final results. presented at 2004 ASCO Annual Meeting. 2004.
32 Garufi C, Nistico C, Brienza S, et al. Single-agent oxaliplatin in pretreated advanced breast cancer patients: a phase II study. Annals of Oncology. 2001;12(2):179-182. [pmid: 11300320].
33 Cottu P, Caruba T, Espié M, Madelaine-Chambrin I, Misset J, Gross-Goupil M. Gemcitabine combined with oxaliplatin in advanced breast cancer: Updated results of two parallel phase II studies. presented at 2005 ASCO Annual Meeting. 2005.
34 Zelek L, Cottu P, Tubiana-Hulin M, et al. Phase II study of oxaliplatin and fluorouracil in taxane- and anthracycline-pretreated breast cancer patients. Journal of Clinical Oncology. 2002;20(10):2551-2558. [pmid: 12011135].
35 Caussanel J, Levi F, Brienza S, et al. Phase I trial of 5-day continuous venous infusion of oxaliplatin at circadian rhythm-modulated rate compared with constant rate. Journal of the National Cancer Institute. 1990;82(12):1046-1050. [pmid: 2348469].
36 Gebbia N, Fulfaro F, Badalamenti G, et al. A phase 2 study of oxaliplatin (O) – capecitabine (C) chemotherapy in metastatic breast cancer (MBC) patients pretreated with anthracyclines and taxanes. presented at 2004 ASCO Annual Meeting. 2004.
37 Pectasides D, Pectasides M, Farmakis D, et al. Oxaliplatin plus high-dose leucovorin and 5-fluorouracil in pretreated advanced breast cancer: a phase II study. Annals of Oncology. 2003;14(4):537-542. [pmid: 12649097].
38 Thuss-Patience PC, von Minckwitz G, Kretzschmar A, et al. Oxaliplatin and 5-fluorouracil for heavily pretreated metastatic breast cancer: a preliminary phase II study. Anti-Cancer Drugs. 2003;14(7):549-553. [pmid: 12960739].
39 Leonardi V, Savio G, Laudani A, Blasi L, Agostara B. New approaches to breast cancer: oxaliplatin combined with 5-fluorouracil and folinic acid in pretreated advanced breast cancer patients: preliminary reports. Annals of the New York Academy of Sciences. 2002;963:91-97. [pmid: 12095933].
40 Bidoli P, Cortinovis D, Isa L, et al. Preliminary results of a randomized phase II three-arm, multicentric study of carboplatin + gemcitabine (CBDCA + GEM), or oxaliplatin (L-OHP) + GEM, or sequential CBDCA + GEM? docetaxel (DCT) + GEM in chemo-naive patients (pts) with advanced/metastatic non small cell lung cancer (NSCLC). presented at 2005 ASCO Annual Meeting. 2005.
41 Scagliotti GV, Kortsik C, Dark GG, et al. Pemetrexed combined with oxaliplatin or carboplatin as first-line treatment in advanced non-small cell lung cancer: a multicenter, randomized, phase II trial. Clinical Cancer Research. 2005;11(2 Pt 1):690-696. [pmid: 15701857].
42 Lippe P, Mazzanti P, Recchia F, et al. Gemcitabine-oxaliplatin combination (GEM-OHP) in metastatic non-small cell lung cancer (NSCLC): Final results of a phase II study. presented at 2005 ASCO Annual Meeting. 2005.
43 Broad A, Links M, Rosenthal M, Mitchell P. Combination gemcitabine and oxaliplatin for advanced non small cell lung cancer (NSCLC): An Australian multicenter randomized phase II sequencing trial. presented at 2005 ASCO Annual Meeting. 2005.
44 Cappuzzo F, Novello S, De Marinis F, et al. Phase II study of gemcitabine plus oxaliplatin as first-line chemotherapy for advanced non-small-cell lung cancer. British Journal of Cancer. 2005;93(1):29-34. [pmid: 15956971].
45 Kouroussis C, Androulakis N, Vamvakas L, et al. Phase I study of weekly docetaxel and liposomal doxorubicin in patients with advanced solid tumors. Oncology. 2005;69(3):202-207. [pmid: 16127289].
46 Santos E, Raez L, Rocha-Lima C, et al. Oxaliplatin and Docetaxel as First Line Chemotherapy for Patients with Non-Small Cell Lung Cancer (NSCLC). presented at 2005 ASCO Annual Meeting. 2005.
47 Buosi R, Poletti S, Cantele V, et al. Preliminary results of phase II trial with combination of gemcitabine and oxaliplatin in elderly patients with advanced NSCLC. journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2004;22(14S).
48 Winegarden JD, Mauer AM, Otterson GA, et al. A phase II study of oxaliplatin and paclitaxel in patients with advanced non-small-cell lung cancer. Annals of Oncology. 2004;15(6):915-920. [pmid: 15151948].
49 Franciosi V, Barbieri R, Aitini E, et al. Gemcitabine and oxaliplatin: a safe and active regimen in poor prognosis advanced non-small cell lung cancer patients. Lung Cancer. 2003;41(1):101-106. [pmid: 12826318].
50 Monnet I, de CH, Soulie P, et al. Oxaliplatin plus vinorelbine in advanced non-small-cell lung cancer: final results of a multicenter phase II study. Annals of Oncology. 2002;13(1):103-107. [pmid: 11863089].
51 Monnet I, Brienza S, Hugret F, et al. Phase II study of oxaliplatin in poor-prognosis non-small cell lung cancer (NSCLC). ATTIT. Association pour le Traitement des Tumeurs Intra Thoraciques. European Journal of Cancer. 1998;34(7):1124-1127. [pmid: 9849465].
52 Faivre S, Le Chevalier T, Monnerat C, et al. Phase I-II and pharmacokinetic study of gemcitabine combined with oxaliplatin in patients with advanced non-small-cell lung cancer and ovarian carcinoma. Annals of Oncology. 2002;13(9):1479-1489. [pmid: 12196375].
53 Monnet I, Soulie P, de Cremoux H, et al. Phase I/II study of escalating doses of vinorelbine in combination with oxaliplatin in patients with advanced non-small-cell lung cancer. Journal of Clinical Oncology. 2001;19(2):458-663. [pmid: 11208839].
54 Bidoli P, Stani SC, Mariani L, et al. Phase I study of escalating doses of oxaliplatin in combination with fixed dose gemcitabine in patients with non-small cell lung cancer. Lung Cancer. 2004;43(2):203-208. [pmid: 14739041].
55 Doroshow JH, Synold TW, Gandara D, et al. Pharmacology of oxaliplatin in solid tumor patients with hepatic dysfunction: a preliminary report of the National Cancer Institute Organ Dysfunction Working Group. Seminars in Oncology. 2003;30(4 Suppl 15):14-19. [pmid: 14523790].
56 Kouroussis C, Agelaki S, Mavroudis D, et al. A dose escalation study of docetaxel and oxaliplatin combination in patients with metastatic breast and non-small cell lung cancer. Anticancer Research. 2003;23(1B):785-791. [pmid: 12680184].
57 Kakolyris S, Kouroussis C, Koukourakis M, et al. A dose-escalation study of oxaliplatin and vinorelbine in patients with advanced solid tumors. Oncology. 2002;63(3):213-218. [pmid: 12381899].
58 Santini D, Tonini G, Salerno A, et al. Idiosyncratic reaction after oxaliplatin infusion.[see comment]. Annals of Oncology. 2001;12(1):132-133. [pmid: 11249043].
59 Perez EA, Hillman DW, Mailliard JA, et al. Randomized phase II study of two irinotecan schedules for patients with metastatic breast cancer refractory to an anthracycline, a taxane, or both. Journal of Clinical Oncology. 2004;22(14):2849-2855. [pmid: 15254052].
60 Vukelja S, O'Shaughnessy J, Campos S, et al. Activity of oral irinotecan (IRI) in metastatic breast cancer (MBC) patients after prior anthracycline, taxane and capecitabine: Phase 2 study results. presented at 2005 ASCO Annual Meeting. 2005.
61 Agelaki S, Karyda E, Kouroussis C, et al. Gemcitabine plus irinotecan in breast cancer patients pretreated with taxanes and anthracyclines: a multicenter phase II study. Oncology. 2003;64(4):477-478. [pmid: 12759550].
62 Frasci G, D'Aiuto G, Thomas R, et al. Biweekly docetaxel-irinotecan treatment with filgrastim support is highly active in antracycline-Paclitaxel-refractory breast cancer patients. Oncology. 2005;68(4–6):391-397. [pmid: 16020968].
63 Moulder S, Munster P, Minton S, et al. Results of a planned efficacy and safety analysis for a National Comprehensive Cancer Network sponsored phase II study of gemcitabine and irinotecan (GI) in metastatic breast cancer (MBC). presented at 2005 ASCO Annual Meeting. 2005.
64 Gold P, Refice S, West H. Phase I trial of irinotecan and epirubicin in patients with advanced solid tumors. presented at 2005 ASCO Annual Meeting. 2005.
65 Faivre S, Delbaldo C, Pautier P, et al. Phase I study of ixabepilone given every other week in combination with irinotecan in patients with advanced malignancies. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2004;22(14S).
66 Frasci G, Comella P, Thomas R, et al. Biweekly docetaxel-irinotecan with filgrastim support in pretreated breast and non-small-cell lung cancer patients. A phase I study. Cancer Chemotherapy & Pharmacology. 2004;53(1):25-32. [pmid: 14513281].
67 Verschraegen CF, Lee FC, Rabinowitz I, et al. Phase I and translational study of capecitabine, cisplatin, and irinotecan in patients with solid tumors. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2004;22(14S).
68 Shigeoka Y, Itoh K, Igarashi T, et al. Clinical effect of irinotecan in advanced and metastatic breast cancer patients previously treated with doxorubicin- and docetaxel-containing regimens. Japanese Journal of Clinical Oncology. 2001;31(8):370-374. [pmid: 11574629].
69 Rothenberg ML. Topoisomerase I inhibitors: review and update. Annals of Oncology. 1997;8(9):837-855. [pmid: 9358934].
70 Burris HA 3rd, Fields SM. Topoisomerase I inhibitors. An overview of the camptothecin analogs. Hematology - Oncology Clinics of North America. 1994;8(2):333-355.
71 Ajani JA, Fodor MB, Tjulandin SA, et al. Phase II multi-institutional randomized trial of docetaxel plus cisplatin with or without fluorouracil in patients with untreated, advanced gastric, or gastroesophageal adenocarcinoma.[see comment]. Journal of Clinical Oncology. 2005;23(24):5660-5667. [pmid: 16110025].
72 Burtness B, Gibson M, Lacy J, et al. Phase II trial of docetaxel/irinotecan therapy in metastatic esophageal cancer: evidence for activity in previously untreated patients. presented at 2005 ASCO Annual Meeting. 2005.
73 Kajiyama Y, Okumura M, Isayama F, et al. Weekly docetaxel (D) versus daily low dose cisplatin (P)/fluorouracil (F) as neoadjuvant chemoradiotherapy (CRT) in patients with advanced esophageal cancer: Nonrandomized Phase II results of a single institute. presented at 2005 ASCO Annual Meeting. 2005.
74 Lorenzen S, Duyster J, Lersch C, et al. Three-weekly Docetaxel (T) plus Capecitabine (X) in 1st and 2nd Line Metastatic Esophageal Cancer (MEC): Final Results of the Phase II DACAPO Trial. presented at 2005 ASCO Annual Meeting. 2005.
75 Lorenzen S, Duyster J, Lersch C, et al. Capecitabine plus docetaxel every 3 weeks in first- and second-line metastatic oesophageal cancer: final results of a phase II trial. British Journal of Cancer. 2005;92(12):2129-2133. [pmid: 15942631].
76 Muro K, Hamaguchi T, Ohtsu A, et al. A phase II study of single-agent docetaxel in patients with metastatic esophageal cancer. Annals of Oncology. 2004;15(6):955-959. [pmid: 15151954].
77 Posey J, Thornton J, Russo S, Cerfolio R, Heslin M, Eloubeidi M. A phase II study of irinotecan and docetaxel with concurrent radiotherapy as preoperative treatment in resectable esophageal cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2004;22(14S).
78 Airoldi M, Cortesina G, Giordano C, Pedani F, Bumma C, Gabriele P. Docetaxel and vinorelbine: an effective regimen in recurrent squamous cell esophageal carcinoma. Medical Oncology. 2003;20(1):19-24. [pmid: 12665680].
79 Govindan R, Read W, Faust J, et al. Phase II study of docetaxel and irinotecan in metastatic or recurrent esophageal cancer: a preliminary report. Oncology (Huntington). 9 Suppl 8. 2003;17:27-31.
80 Lordick F, von Schilling C, Bernhard H, Hennig M, Bredenkamp R, Peschel C. Phase II trial of irinotecan plus docetaxel in cisplatin-pretreated relapsed or refractory oesophageal cancer. British Journal of Cancer. 2003;89(4):630-633. [pmid: 12915869].
81 Schull B, Kornek GV, Schmid K, et al. Effective combination chemotherapy with bimonthly docetaxel and cisplatin with or without hematopoietic growth factor support in patients with advanced gastroesophageal cancer. Oncology. 2003;65(3):211-217. [pmid: 14657594].
82 Font A, Garcia-Alfonso P, Arellano A, al. E. Preoperative combined multimodal therapy with docetaxel plus 5-fluorouracil and concurrent hyperfrationated radiotherapy for locally advanced esophageal cancer. Proc ASCO. 2002;21:128b.
83 Heath EI, Urba S, Marshall J, Piantadosi S, Forastiere AA. Phase II trial of docetaxel chemotherapy in patients with incurable adenocarcinoma of the esophagus. Investigational New Drugs. 2002;20(1):95-99. [pmid: 12003198].
84 Jatoi A, Tirona MT, Cha SS, et al. A phase II trial of docetaxel and CPT-11 in patients with metastatic adenocarcinoma of the esophagus, gastroesophageal junction, and gastric cardia. International Journal of Gastrointestinal Cancer. 2002;32(2‒3):115-123. [pmid: 12794247].
85 Ridwelski K, Gebauer T, Fahlke J, et al. Combination chemotherapy with docetaxel and cisplatin for locally advanced and metastatic gastric cancer. Annals of Oncology. 2001;12(1):47-51. [pmid: 11249048].
86 Ajani J, Fodor M, Van Cutsem E, et al. Multinational randomized phase II trial of docetaxel (T) and cisplatin (C) with or without 5-fluorouracil (FU) in patients (Pts) with advanced gastric or GE junction adenocarcinoma (AGC-AGEJC). 2000 ASCO Annual Meeting. 2000.
87 Eniu A, Ciuleanu TE, Todor N, Ghilezan N. Docetaxel, 5-fluorouracil and leucovorin (DFL): An outpatient first line palliative regimen for advanced/metastatic gastric cancer. Ann Oncol. Suppl 4. 2000;11:65. [pmid: 10690389].
88 Giuliani F, Gebbia V, De Vita F, et al. Docetaxel (Taxotere) as salvage chemotherapy in patients with advanced gastric cancer. A phase II study of the Southern Italian Oncology Group (GOIM). Ann Oncol. Suppl 4. 2000;11:67.
89 Mauer A, Haraf D, Ferguson M, et al. Docetaxel-based combined modality therapy for locally advanced carcinoma of the esophagus and gastric cardia. Proc Am Soc Clin Oncology. 2000;19:246a.
90 Mavroudis D, Kourousis C, Androulakis N, et al. Frontline treatment of advanced gastric cancer with docetaxel and granulocyte colony-stimulating factor (G-CSF): a phase II trial. American Journal of Clinical Oncology. 2000;23(4):341-344. [pmid: 10955859].
91 Thuss-Patience PC, Kretzschmar A, Vielhaber A, Dorken B, P R. Docetaxel and 5-FU continuous infusion (DF) versus epirubicin, cisplatin and 5-FU (ECF) for advanced gastric adenocarcinoma: A randomised phase II study. Ann Oncol. Suppl 4. 2000;11:67.
92 Einzig AI, Neuberg D, Remick SC, et al. Phase II trial of docetaxel (Taxotere) in patients with adenocarcinoma of the upper gastrointestinal tract previously untreated with cytotoxic chemotherapy: the Eastern Cooperative Oncology Group (ECOG) results of protocol E1293. Medical Oncology. 1996;13(2):87-93. [pmid: 9013471].
93 Sulkes A, Smyth J, Sessa C, et al. Docetaxel (Taxotere) in advanced gastric cancer: results of a phase II clinical trial. EORTC Early Clinical Trials Group.[see comment]. British Journal of Cancer. 1994;70(2):380-383. [pmid: 7914428].
94 Pasini F, de Manzoni G, Pedrazzani C, et al. High pathological response rate in locally advanced esophageal cancer after neoadjuvant combined modality therapy: dose finding of a weekly chemotherapy schedule with protracted venous infusion of 5-fluorouracil and dose escalation of cisplatin, docetaxel and concurrent radiotherapy. Annals of Oncology. 2005;16(7):1133-1139. [pmid: 15946974].
95 Tsai JY, Iannitti D, Berkenblit A, et al. Phase I study of docetaxel, capecitabine, and carboplatin in metastatic esophagogastric cancer. American Journal of Clinical Oncology. 2005;28(4):329-333. [pmid: 16062072].
96 Yuki S, Komatsu Y, Machida N, et al. Phase I study of docetaxel, cisplatin and 5-fluorouracil(TPF) as first-line chemotherapy in patients with advanced esophageal cancer. -Hokkaido Gastrointestinal Cancer Study Group(HGCSG) study-. presented at 2005 ASCO Annual Meeting. 2005.
97 Bubis J, Williams I, Dragnev K, et al. Docetaxel (DTX) and carboplatin (CP) followed by a dose-ranging study of oral capecitabine, weekly DTX, concomitant radiotherapy and surgery for the treatment of patients with stage II-III carcinoma of the esophagus. presented at 2004 ASCO Annual Meeting. 2004.
98 Enzinger PC, Clark J, Ryan D, et al. Phase II study of docetaxel, cisplatin, and irinotecan in advanced esophageal and gastric cancer. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2004;22(14S). (July 15 Supplement) #4040.
99 Roth A, de Pree C, Majno S, et al. Curative preoperative treatment with docetaxel (Taxotere)-cisplatin-5FU (TCF) combined with hyperfractionated radiation therapy in locally advanced cancer of the esophagus: A phase I-II study. Ann Oncol. Suppl 4. 2000;11:70.
100 Roth AD, Maibach R, Martinelli G, et al. Docetaxel (Taxotere)-cisplatin (TC): an effective drug combination in gastric carcinoma. Swiss Group for Clinical Cancer Research (SAKK), and the European Institute of Oncology (EIO). Annals of Oncology. 2000;11(3):301-306. [pmid: 10811496].
101 Mauer AM, Masters GA, Haraf DJ, et al. Phase I study of docetaxel with concomitant thoracic radiation therapy. Journal of Clinical Oncology. 1998;16(1):159-164. [pmid: 9440738].
102 Syed S, Calvo E, Papadopoulos K, et al. A phase I and pharmacokinetic study of Thymitaq® (nolatrexed dihydrochloride), a potent thymidylate synthase (TS) inhibitor, combined with docetaxel in patients with advanced cancer. presented at 2005 ASCO Annual Meeting. 2005.
103 Poole M, Churchel M, Bernard S. Phase I Study of Gemcitabine and Docetaxel for Locally Advanced and/or Metastatic Cancer of the Head and Neck, Non-Colorectal Gastrointestinal Cancer, Hepatoma, and Soft Tissue Sarcoma. Proc Am Soc Clin Oncology. 2000;19:222a.
104 Puccio C, Chun H, Olson C, Policastro A, Mittelman A. Continuous Infusion (CI) 5-Fluorouracil (5-FU) Plus Weekly Docetaxel: An Active Regimen for Elderly Patients (Pts) with Advanced or Metastatic Cancer of the Stomach and Distal Esophagus. Proc Am Soc Clin Oncology. 2000;19:272a.
105 Ryan DP, Lynch TJ, Grossbard ML, et al. A phase I study of gemcitabine and docetaxel in patients with metastatic solid tumors. Cancer. 2000;88(1):180-185. [pmid: 10618622].
106 Vokes EE, Mauer AM, Hoffman PC, Haraf DJ. Combined modality therapy in non-small cell lung and esophageal cancer: a phase I dose-escalation study of docetaxel with concurrent radiotherapy. Seminars in Oncology. 1998;25(3 Suppl 8):28-32. [pmid: 9704674].
107 Esmaeli B, Hidaji L, Adinin RB, et al. Blockage of the lacrimal drainage apparatus as a side effect of docetaxel therapy. Cancer. 2003;98(3):504-507. [pmid: 12879466].
108 Jani AB, Connell PP, Vesich VJ, O'Brien KM, Chen LM. Analysis of the role of adjuvant chemotherapy for invasive carcinoma of the esophagus. American Journal of Clinical Oncology. 2000;23(6):554-558. [pmid: 11202794].
109 Verweij J, Catimel G, Sulkes A, et al. Phase II studies of docetaxel in the treatment of various solid tumours. EORTC Early Clinical Trials Group and the EORTC Soft Tissue and Bone Sarcoma Group. European Journal of Cancer. Suppl 4. 1995;31A:S21-S24. [pmid: 7577101].
110 Anonymous. Reviewer's concensus on the use of docetaxel for the treatment of esophageal and gastric carcinomas. [citation per USP-DI, unable to confirm]. 2001.
111 Package Insert. Taxotere [package insert]. 2004.
112 Textbook. Pharmacotherapy: a Pathophysiologic Approach. New York, NY. McGraw-Hill. 2002. 4th ed.
113 Database. Docetaxel: Cancer Chemotherapy Manual: eFacts (available from Wolters Kluwer Health, Inc.). 2005.
114 Elsaid A, Elkerm Y. Final results of a randomized phase III trial of Docetaxel, Carboplatin and 5FU versus Epirubicin, cisplatin and 5FU for locally advanced gastric cancer. presented at 2005 ASCO Annual Meeting. 2005.
115 Fahlke J, Ridwelski K, Schmidt C, et al. Docetaxel-cisplatin (DC) versus 5-fluorouracil-leucovorin-cisplatin (FLC) as first-line treatment for locally advanced or metastatic gastric cancer: preliminary safety results of a Phase III study. presented at 2005 ASCO Annual Meeting. 2005.
116 Moiseyenko V, Ajani J, Tjulandin S, et al. Final results of a randomized controlled phase III trial (TAX 325) comparing docetaxel (T) combined with cisplatin (C) and 5-fluorouracil (F) to CF in patients (pts) with metastatic gastric adenocarcinoma (MGC). presented at 2005 ASCO Annual Meeting. 2005.
117 Vasey PA, Jayson GC, Gordon A, et al. Phase III randomized trial of docetaxel-carboplatin versus paclitaxel-carboplatin as first-line chemotherapy for ovarian carcinoma. Journal of the National Cancer Institute. 2004;96(22):1682-1691. [pmid: 15547181].
118 Markman M, Liu P, Wilczynski S, et al. Phase III randomized trial of 12 versus 3 months of maintenance paclitaxel in patients with advanced ovarian cancer after complete response to platinum and paclitaxel-based chemotherapy: a Southwest Oncology Group and Gynecologic Oncology Group trial.[see comment]. Journal of Clinical Oncology. 2003;21(13):2460-2465. [pmid: 12829663].
119 Parmar MKB, Ledermann JA, Colombo N, et al. Paclitaxel plus platinum-based chemotherapy versus conventional platinum-based chemotherapy in women with relapsed ovarian cancer: the ICON4/AGO-OVAR-2.2 trial.[see comment]. Lancet. 2003;361(9375):2099-2106. [pmid: 12826431].
120 Polyzos A, Kosmas C, Toufexi H, et al. Docetaxel in combination with irinotecan (CPT-11) in platinum-resistant paclitaxel-pretreated ovarian cancer. Anticancer Research. 2005;25(5):3559-3564. [pmid: 16101180].
121 Berkenblit A, Seiden MV, Matulonis UA, et al. A phase II trial of weekly docetaxel in patients with platinum-resistant epithelial ovarian, primary peritoneal serous cancer, or fallopian tube cancer. Gynecologic Oncology. 2004;95(3):624-631. [pmid: 15581974].
122 Dieras V, Guastalla JP, Ferrero JM, et al. A multicenter phase II study of cisplatin and docetaxel (Taxotere) in the first-line treatment of advanced ovarian cancer: a GINECO study. Cancer Chemotherapy & Pharmacology. 2004;53(6):489-495. [pmid: 14767617].
123 Markman M, Webster K, Zanotti K, Peterson G, Kulp B, Belinson J. Survival following the documentation of platinum and taxane resistance in ovarian cancer: a single institution experience involving multiple phase 2 clinical trials.[see comment]. Gynecologic Oncology. 2004;93(3):699-701. [pmid: 15196867].
124 Aravantinos G, Bafaloukos D, Fountzilas G, et al. Phase II study of docetaxel-vinorelbine in platinum-resistant, paclitaxel-pretreated ovarian cancer. Annals of Oncology. 2003;14(7):1094-1099. [pmid: 12853352].
125 Markman M, Zanotti K, Webster K, Peterson G, Kulp B, Belinson J. Phase 2 trial of single agent docetaxel in platinum and paclitaxel-refractory ovarian cancer, fallopian tube cancer, and primary carcinoma of the peritoneum. Gynecologic Oncology. 2003;91(3):573-576. [pmid: 14675679].
126 Rose PG, Blessing JA, Ball HG, et al. A phase II study of docetaxel in paclitaxel-resistant ovarian and peritoneal carcinoma: a Gynecologic Oncology Group study. Gynecologic Oncology. 2003;88(2):130-135. [pmid: 12586591].
127 Vorobiof DA, Rapoport BL, Chasen MR, Cohen GL, Mahomed R, Karime M. Phase II clinical trial of carboplatin and docetaxel in patients with metastatic ovarian cancer: active combination with low incidence of peripheral neuropathy. International Journal of Gynecological Cancer. 2003;13(3):287-291. [pmid: 12801257].
128 Laport GG, Fleming GF, Waggoner S, Zimmerman TM, Grinblatt DL, Williams SF. A phase II trial of docetaxel for peripheral blood stem cell mobilization for patients with breast cancer and ovarian cancer. Bone Marrow Transplantation. 2001;27(7):677-681. [pmid: 11360105].
129 Markman M, Kennedy A, Webster K, Peterson G, Kulp B, Belinson J. Combination chemotherapy with carboplatin and docetaxel in the treatment of cancers of the ovary and fallopian tube and primary carcinoma of the peritoneum. Journal of Clinical Oncology. 2001;19(7):1901-1905. [pmid: 11283121].
130 Katsumata N, Tsunematsu R, Tanaka K, et al. A phase II trial of docetaxel in platinum pre-treated patients with advanced epithelial ovarian cancer: a Japanese cooperative study. Annals of Oncology. 2000;11(12):1531-1536. [pmid: 11205459].
131 Vasey PA, Paul J, Birt A, et al. Docetaxel and cisplatin in combination as first-line chemotherapy for advanced epithelial ovarian cancer. Scottish Gynaecological Cancer Trials Group. Journal of Clinical Oncology. 1999;17(7):2069-2080. [pmid: 10561260].
132 Kavanagh JJ, Kudelka AP, de Leon CG, et al. Phase II study of docetaxel in patients with epithelial ovarian carcinoma refractory to platinum. Clinical Cancer Research. 1996;2(5):837-842. [pmid: 9816238].
133 Kaye SB, Piccart M, Aapro M, Kavanagh J. Docetaxel in advanced ovarian cancer: preliminary results from three phase II trials. EORTC Early Clinical Trials Group and Clinical Screening Group, and the MD Anderson Cancer Center. European Journal of Cancer. Suppl 4. 1995;31A:S14-S17. [pmid: 7577099].
134 Piccart MJ, Gore M, Ten Bokkel Huinink W, et al. Docetaxel: an active new drug for treatment of advanced epithelial ovarian cancer. Journal of the National Cancer Institute. 1995;87(9):676-681. [pmid: 7752272].
135 Aapro M, Pujade-Lauraine E, Lhomme C, et al. EORTC clinical screening group: Phase II study of Taxotere (docetaxel) in ovarian cancer. Ann Oncol. Suppl 5. 1994;5:202.
136 Fossella FV, Lee JS, Murphy WK, et al. Phase II study of docetaxel for recurrent or metastatic non-small-cell lung cancer. Journal of Clinical Oncology. 1994;12(6):1238-1244. [pmid: 7911160].
137 Francis P, Schneider J, Hann L, et al. Phase II trial of docetaxel in patients with platinum-refractory advanced ovarian cancer. Journal of Clinical Oncology. 1994;12(11):2301-2308. [pmid: 7964944].
138 McGuire WP, Rowinsky EK, Rosenshein NB, et al. Taxol: a unique antineoplastic agent with significant activity in advanced ovarian epithelial neoplasms. Annals of Internal Medicine. 1989;111(4):273-279. [pmid: 2569287].
139 Pfisterer J, du Bois A, Wagner U, et al. Docetaxel and carboplatin as first-line chemotherapy in patients with advanced gynecological tumors. A phase I/II trial of the Arbeitsgemeinschaft Gynakologische Onkologie (AGO-OVAR) Ovarian Cancer Study Group. Gynecologic Oncology. 2004;92(3):949-956. [pmid: 14984965].
140 Komiyama S, Tsuji H, Asai S, Dokoh J, Ishikawa M, Mikami M. A pilot study of weekly docetaxel therapy for recurrent ovarian cancer, tubal cancer, and primary peritoneal cancer. European Journal of Gynaecological Oncology. 2005;26(3):299-302. [pmid: 15991531].
141 Berkenblit A, Tung N, Kim Y, et al. Phase I trial of docetaxel, carboplatin, and gemcitabine as first-line therapy for patients with high-risk epithelial tumors of mullerian origin. Gynecologic Oncology. 2003;89(3):486-493. [pmid: 12798716].
142 de Bree E, Romanos J, Michalakis J, et al. Intraoperative hyperthermic intraperitoneal chemotherapy with docetaxel as second-line treatment for peritoneal carcinomatosis of gynaecological origin. Anticancer Research. 2003;23(3C):3019-3027. [pmid: 12926156].
143 de Bree E, Rosing H, Beijnen JH, et al. Pharmacokinetic study of docetaxel in intraoperative hyperthermic i.p. chemotherapy for ovarian cancer. Anti-Cancer Drugs. 2003;14(2):103-110. [pmid: 12569296].
144 Morgan RJ Jr, Doroshow JH, Synold T, et al. Phase I trial of intraperitoneal docetaxel in the treatment of advanced malignancies primarily confined to the peritoneal cavity: dose-limiting toxicity and pharmacokinetics. Clinical Cancer Research. 2003;9(16 Pt 1):5896-5901. [pmid: 14676112].
145 Oishi T, Kigawa J, Fujiwara K, et al. A feasibility study on biweekly administration of docetaxel for patients with recurrent ovarian cancer. Gynecologic Oncology. 2003;90(2):421-424. [pmid: 12893211].
146 Terauchi F, Hirano T, Taoka H, et al. Weekly docetaxel for patients with platinum/paclitaxel/irinotecan-resistant relapsed ovarian cancer: a phase I study. International Journal of Clinical Oncology. 2003;8(6):348-351. [pmid: 14663635].
147 O'Neill VJ, Kaye SB, Reed NS, Paul J, Davis JA, Vasey PA. A dose-finding study of carboplatin-epirubicin-docetaxel in advanced epithelial ovarian cancer. British Journal of Cancer. 2002;86(9):1385-1390. [pmid: 11986768].
148 Vasey PA, Atkinson R, Coleman R, et al. Docetaxel-carboplatin as first line chemotherapy for epithelial ovarian cancer. British Journal of Cancer. 2001;84(2):170-178. [pmid: 11161372].
149 Soulie P, Bensmaine A, Garrino C, et al. Oxaliplatin/cisplatin (L-OHP/CDDP) combination in heavily pretreated ovarian cancer. European Journal of Cancer. 1997;33(9):1400-1406. [pmid: 9337681].
150 Tomiak E, Piccart M, Kerger J, et al. Phase I study of docetaxel administered as a 1-hour intravenous infusion on a weekly basis. Journal of Clinical Oncology. 1994;12(7):1458-1467. [pmid: 7912725].
151 Huizing MT, Keung AC, Rosing H, et al. Pharmacokinetics of paclitaxel and metabolites in a randomized comparative study in platinum-pretreated ovarian cancer patients. Journal of Clinical Oncology. 1993;11(11):2127-2135. [pmid: 7901342].
152 Pazdur R, Newman RA, Newman BM, et al. Phase I trial of Taxotere: five-day schedule. Journal of the National Cancer Institute. 1992;84(23):1781-1788. [pmid: 1359154].
153 Brown J, Shvartsman HS, Deavers MT, et al. The activity of taxanes compared with bleomycin, etoposide, and cisplatin in the treatment of sex cord-stromal ovarian tumors. Gynecologic Oncology. 2005;97(2):489-496. [pmid: 15863149].
154 Kuribayashi K, Matsunaga T, Sakai T, et al. A patient with TP53 germline mutation developed Bowen's disease and myelodysplastic syndrome with myelofibrosis after chemotherapy against ovarian cancer.[see comment]. Internal Medicine. 2005;44(5):490-495. [pmid: 15942101].
155 Martino MA, Miller E, Grendys EC Jr. The administration of chemotherapy in a patient with Charcot-Marie-Tooth and ovarian cancer. Gynecologic Oncology. 2005;97(2):710-712. [pmid: 15863189].
156 Montero A, Fossella F, Hortobagyi G, Valero V. Docetaxel for treatment of solid tumours: a systematic review of clinical data. Lancet Oncology. 2005;6(4):229-239.
157 Watanabe A, Shimada M, Kigawa J, et al. The benefit of chemotherapy in a patient with multiple brain metastases and meningitis carcinomatosa from ovarian cancer. International Journal of Clinical Oncology. 2005;10(1):69-71. [pmid: 15729605].
158 Brown J, Shvartsman HS, Deavers MT, Burke TW, Munsell MF, Gershenson DM. The activity of taxanes in the treatment of sex cord-stromal ovarian tumors. Journal of Clinical Oncology. 2004;22(17):3517-3523. [pmid: 15337800].
159 Hsu Y, Sood AK, Sorosky JI. Docetaxel versus paclitaxel for adjuvant treatment of ovarian cancer: case-control analysis of toxicity. American Journal of Clinical Oncology. 2004;27(1):14-18. [pmid: 14758127].
160 Finsterer J, Bodenteich A, Drlicek M. Atypical paraneoplastic syndrome associated with anti-Yo antibodies. Clinical Neuropathology. 2003;22(3):137-140. [pmid: 12809356].
161 Komiyama S, Mizusawa Y, Onouchi M, Takehara K, Suzuki A, Mikami M. Effective weekly docetaxel for recurrent ovarian cancer: A case report. International Journal of Gynecological Cancer. 2003;13(5):683-686. [pmid: 14675355].
162 McNally OM, Delaney E, Petty RD, Cruickshank ME, Hutcheon AW, Parkin DE. Is optimal first-line chemotherapy deliverable in all newly diagnosed ovarian cancers? A population-based study.[comment]. British Journal of Cancer. 2003;89(6):966-967. [pmid: 12966409].
163 Niwa Y, Nakanishi T, Kuzuya K, Nawa A, Mizutani S. Salvage treatment with docetaxel for recurrent epithelial ovarian cancer. International Journal of Clinical Oncology. 2003;8(6):343-347. [pmid: 14663634].
164 Aoki Y, Sato T, Tsuneki I, et al. Docetaxel in combination with carboplatin for chemo-naive patients with epithelial ovarian cancer. International Journal of Gynecological Cancer. 2002;12(6):704-709. [pmid: 12445246].
165 Hirai K, Ishiko O, Nakajima S, et al. Local erythematous dermatitis after intravenous docetaxel. Gynecologic & Obstetric Investigation. 2002;53(2):118-120. [pmid: 11961387].
166 Jeyakumar A, Chalas E, Hindenburg A. Sustained complete remission in a patient with platinum-resistant ovarian yolk sac tumor. Gynecologic Oncology. 2001;82(3):578-580. [pmid: 11520160].
167 Kouroussis C, Samonis G, Androulakis N, et al. Successful conservative treatment of neutropenic enterocolitis complicating taxane-based chemotherapy: a report of five cases. American Journal of Clinical Oncology. 2000;23(3):309-313. [pmid: 10857900].
168 Lister-Sharp D, McDonagh MS, Khan KS, Kleijnen J. A rapid and systematic review of the effectiveness and cost-effectiveness of the taxanes used in the treatment of advanced breast and ovarian cancer. Health Technology Assessment (Winchester, England). 2000;4(17):1-113.
169 Verschraegen CF, Sittisomwong T, Kudelka AP, et al. Docetaxel for patients with paclitaxel-resistant Mullerian carcinoma. Journal of Clinical Oncology. 2000;18(14):2733-2739. [pmid: 10894873].
170 Benjapibal M, Kudelka AP, Vasuratna A, et al. Docetaxel and cyclophosphamide induced remission in platinum and paclitaxel refractory ovarian cancer. Anti-Cancer Drugs. 1998;9(6):577-579. [pmid: 9877247].
171 Eisenhauer EA, Vermorken JB. The taxoids. Comparative clinical pharmacology and therapeutic potential. Drugs. 1998;55(1):5-30. [pmid: 9463787].
172 Balat O, Kudelka AP, Edwards CL, Verschraegen CF, Kavanagh JJ. Prolonged remission of platinum-refractory ovarian cancer with docetaxel: brief report and review of literature. European Journal of Gynaecological Oncology. 1997;18(5):341-342. [pmid: 9378149].
173 Behar A, Pujade-Lauraine E, Maurel A, et al. The pathophysiological mechanism of fluid retention in advanced cancer patients treated with docetaxel, but not receiving corticosteroid comedication. British Journal of Clinical Pharmacology. 1997;43(6):653-658. [pmid: 9205828].
174 Kaye SB, Piccart M, Aapro M, Francis P, Kavanagh J. Phase II trials of docetaxel (Taxotere) in advanced ovarian cancer--an updated overview. European Journal of Cancer. 1997;33(13):2167-2170. [pmid: 9470802].
175 Eisenhauer EA, Vermorken JB. New drugs in gynecologic oncology. Current Opinion in Oncology. 1996;8(5):408-414. [pmid: 8914808].
176 Sweeten KM, Gershenson DM, Burke TW, Morris M, Levenback C, Silva EG. Salvage chemotherapy for refractory transitional cell carcinoma of the ovary (TCC). Gynecologic Oncology. 1995;59(2):211-215. [pmid: 7590475].
177 Kavanagh J, Kudelka A, Freedman R, et al. Taxotere (docetaxel): Activity in platin refractory ovarian cancer and amelioration of toxicity. Proc Am Soc Clin Oncology. 1994;13:237.
178 Anonymous. Program Abstracts [citation per DRUGDEX, unable to confirm]. European Congress of Clinical Oncology (ECCO), Jerusalem, Israel. 1993.
179 Pazdur R, Kudelka AP, Kavanagh JJ, Cohen PR, Raber MN. The taxoids: paclitaxel (Taxol) and docetaxel (Taxotere). Cancer Treatment Reviews. 1993;19(4):351-386. [pmid: 8106152].
180 Rowinsky EK, Onetto N, Canetta RM, Arbuck SG. Taxol: the first of the taxanes, an important new class of antitumor agents. Seminars in Oncology. 1992;19(6):646-662. [pmid: 1361079].
181 Kornek GV, Schuell B, Laengle F, et al. Mitomycin C in combination with capecitabine or biweekly high-dose gemcitabine in patients with advanced biliary tract cancer: a randomised phase II trial. Annals of Oncology. 2004;15(3):478-483. [pmid: 14998852].
182 Gebbia V, Giuliani F, Maiello E, et al. Treatment of inoperable and/or metastatic biliary tree carcinomas with single-agent gemcitabine or in combination with levofolinic acid and infusional fluorouracil: results of a multicenter phase II study. Journal of Clinical Oncology. 2001;19(20):4089-4091. [pmid: 11600613].
183 Doval DC, Sekhon JS, Gupta SK, et al. A phase II study of gemcitabine and cisplatin in chemotherapy-naive, unresectable gall bladder cancer. British Journal of Cancer. 2004;90(8):1516-1520. [pmid: 15083178].
184 Alberts SR, Al-Khatib H, Mahoney MR, et al. Gemcitabine, 5-fluorouracil, and leucovorin in advanced biliary tract and gallbladder carcinoma: a North Central Cancer Treatment Group phase II trial. Cancer. 2005;103(1):111-118. [pmid: 15558814].
185 Cho JY, Paik YH, Chang YS, et al. Capecitabine combined with gemcitabine (CapGem) as first-line treatment in patients with advanced/metastatic biliary tract carcinoma. Cancer. 2005;104(12):2753-2758. [pmid: 16294346].
186 Gelibter A, Malaguti P, Di Cosimo S, et al. Fixed dose-rate gemcitabine infusion as first-line treatment for advanced-stage carcinoma of the pancreas and biliary tree. Cancer. 2005;104(6):1237-1245. [pmid: 16078261].
187 Knox JJ, Hedley D, Oza A, et al. Combining gemcitabine and capecitabine in patients with advanced biliary cancer: a phase II trial.[see comment]. Journal of Clinical Oncology. 2005;23(10):2332-2338. [pmid: 15800324].
188 Park J-S, Oh S-Y, Kim S-H, et al. Single-agent gemcitabine in the treatment of advanced biliary tract cancers: a phase II study. Japanese Journal of Clinical Oncology. 2005;35(2):68-73. [pmid: 15709089].
189 Thongprasert S, Napapan S, Charoentum C, Moonprakan S. Phase II study of gemcitabine and cisplatin as first-line chemotherapy in inoperable biliary tract carcinoma. Annals of Oncology. 2005;16(2):279-281. [pmid: 15668284].
190 Andre T, Tournigand C, Rosmorduc O, et al. Gemcitabine combined with oxaliplatin (GEMOX) in advanced biliary tract adenocarcinoma: a GERCOR study. Annals of Oncology. 2004;15(9):1339-1343. [pmid: 15319238].
191 Eng C, Ramathan RK, Wong MK, et al. A Phase II trial of fixed dose rate gemcitabine in patients with advanced biliary tree carcinoma. American Journal of Clinical Oncology. 2004;27(6):565-569. [pmid: 15577433].
192 Hsu C, Shen YC, Yang CH, et al. Weekly gemcitabine plus 24-h infusion of high-dose 5-fluorouracil/leucovorin for locally advanced or metastatic carcinoma of the biliary tract. British Journal of Cancer. 2004;90(9):1715-1719. [pmid: 15150619].
193 Tsavaris N, Kosmas C, Gouveris P, et al. Weekly gemcitabine for the treatment of biliary tract and gallbladder cancer. Investigational New Drugs. 2004;22(2):193-198. [pmid: 14739669].
194 Lin M-H, Chen J-S, Chen HHW, Su W-C. A phase II trial of gemcitabine in the treatment of advanced bile duct and periampullary carcinomas. Chemotherapy. 2003;49(3):154-158. [pmid: 12815209].
195 Malik IA, Aziz Z, Zaidi SHM, Sethuraman G. Gemcitabine and Cisplatin is a highly effective combination chemotherapy in patients with advanced cancer of the gallbladder. American Journal of Clinical Oncology. 2003;26(2):174-177. [pmid: 12714891].
196 Murad AM, Guimaraes RC, Aragao BC, et al. Phase II trial of the use of gemcitabine and 5-fluorouracil in the treatment of advanced pancreatic and biliary tract cancer. American Journal of Clinical Oncology. 2003;26(2):151-154. [pmid: 12714886].
197 Kuhn R, Hribaschek A, Eichelmann K, Rudolph S, Fahlke J, Ridwelski K. Outpatient therapy with gemcitabine and docetaxel for gallbladder, biliary, and cholangio-carcinomas. Investigational New Drugs. 2002;20(3):351-356. [pmid: 12201499].
198 Gallardo JO, Rubio B, Fodor M, et al. A phase II study of gemcitabine in gallbladder carcinoma.[see comment]. Annals of Oncology. 2001;12(10):1403-1406. [pmid: 11762811].
199 Kubicka S, Rudolph KL, Tietze MK, Lorenz M, Manns M. Phase II study of systemic gemcitabine chemotherapy for advanced unresectable hepatobiliary carcinomas. Hepato-Gastroenterology. 2001;48(39):783-789. [pmid: 11462924].
200 Penz M, Kornek GV, Raderer M, et al. Phase II trial of two-weekly gemcitabine in patients with advanced biliary tract cancer. Annals of Oncology. 2001;12(2):183-186. [pmid: 11300321].
201 Raderer M, Hejna MH, Valencak JB, et al. Two consecutive phase II studies of 5-fluorouracil/leucovorin/mitomycin C and of gemcitabine in patients with advanced biliary cancer. Oncology. 1999;56(3):177-180. [pmid: 10202270].
202 Valencak JB, Kornek GV, Raderer M, et al. Gemcitabine for the treatment of advanced biliary tract carcinomas: evaluation of two different dose regimens. Onkologie. 1999;22:498-501.
203 Mezger J, Sauerbruch T, Ko Y, Wolter F, Funk C, Glasmacher A. Phase II study with gemcitabine in gallbladder and biliary tract carcinoma. Onkologie. 1998;21:232-234.
204 Eckel F, Lersch C, Assmann G, Schulte-Frohlinde E. Toxicity of a 24-hour infusion of gemcitabine in biliary tract and pancreatic cancer: a pilot study. Cancer Investigation. 2002;20(2):180-185. [pmid: 11901537].
205 Zanon C, Alabiso O, Grosso M, et al. Intra-arterial continuous infusion for treatment of pancreatic and biliary tract cancer. International Journal of Pancreatology. 2000;27(3):225-233. [pmid: 10952405].
206 Knox JJ, Hedley D, Oza A, Siu LL, Pond GR, Moore MJ. Gemcitabine concurrent with continuous infusional 5-fluorouracil in advanced biliary cancers: a review of the Princess Margaret Hospital experience. Annals of Oncology. 2004;15(5):770-774. [pmid: 15111345].
207 Price P. Cholangiocarcinoma and the role of radiation and chemotherapy. Hepato-Gastroenterology. 2001;48(37):51-52. [pmid: 11268997].
208 Bokemeyer C, Kollmannsberger C, Oettle H, Kanz L. [Current aspects of chemotherapy of metastatic pancreatic and biliary tract carcinomas]. Schweizerische Rundschau fur Medizin Praxis. 2000;89(39):1545-1552.
209 Gallardo J, Rubio B, Ahumada M, Cortes C. [Efficacy of gemcitabine in the gallbladder cancer. Initial experience in 4 cases]. Revista Medica de Chile. 2000;128(9):1025-1030. [pmid: 11349491].
210 Teufel A, Lehnert T, Stremmel W, Rudi J. Chemotherapy with gemcitabine in patients with advanced gallbladder carcinoma. Zeitschrift fur Gastroenterologie. 2000;38(11):909-912. [pmid: 11132538].
211 Verderame F, Mandina P, Abruzzo F, Scarpulla M, Di Leo R. Biliary tract cancer: our experience with gemcitabine treatment. Anti-Cancer Drugs. 2000;11(9):707-708. [pmid: 11129732].
212 Castro MP. Efficacy of gemcitabine in the treatment of patients with gallbladder carcinoma: a case report.[see comment]. Cancer. 1998;82(4):639-641. [pmid: 9477094].
213 Gallardo J, Fodor M, Gamargo C, Orlandi L. Efficacy of gemcitabine in the treatment of patients with gallbladder carcinoma: a case report.[comment]. Cancer. 1998;83(11):2419-2421. [pmid: 9840543].
214 Hejna M, Pruckmayer M, Raderer M. The role of chemotherapy and radiation in the management of biliary cancer: a review of the literature. European Journal of Cancer. 1998;34(7):977-986. [pmid: 9849443].
215 von der Maase H, Hansen SW, Roberts JT, et al. Gemcitabine and cisplatin versus methotrexate, vinblastine, doxorubicin, and cisplatin in advanced or metastatic bladder cancer: results of a large, randomized, multinational, multicenter, phase III study.[see comment]. Journal of Clinical Oncology. 2000;18(17):3068-3077. [pmid: 11001674].
216 von der Maase H, Sengelov L, Roberts JT, et al. Long-term survival results of a randomized trial comparing gemcitabine plus cisplatin, with methotrexate, vinblastine, doxorubicin, plus cisplatin in patients with bladder cancer. Journal of Clinical Oncology. 2005;23(21):4602-4608. [pmid: 16034041].
217 Hoshi S, Ohyama C, Ono K, et al. Gemcitabine plus carboplatin; and gemcitabine, docetaxel, and carboplatin combined chemotherapy regimens in patients with metastatic urothelial carcinoma previously treated with a platinum-based regimen: preliminary report. International Journal of Clinical Oncology. 2004;9(2):125-129. [pmid: 15108045].
218 Lorusso V, Crucitta E, Silvestris N, et al. Randomised, open-label, phase II trial of paclitaxel, gemcitabine and cisplatin versus gemcitabine and cisplatin as first-line chemotherapy in advanced transitional cell carcinoma of the urothelium. Oncology Reports. 2005;13(2):283-287. [pmid: 15643512].
219 Hussain M, Vaishampayan U, Du W, Redman B, Smith DC. Combination paclitaxel, carboplatin, and gemcitabine is an active treatment for advanced urothelial cancer. Journal of Clinical Oncology. 2001;19(9):2527-2533. [pmid: 11331332].
220 Sternberg CN, Calabro F, Pizzocaro G, Marini L, Schnetzer S, Sella A. Chemotherapy with an every-2-week regimen of gemcitabine and paclitaxel in patients with transitional cell carcinoma who have received prior cisplatin-based therapy. Cancer. 2001;92(12):2993-2998. [pmid: 11753976].
221 Ardavanis A, Tryfonopoulos D, Alexopoulos A, Kandylis C, Lainakis G, Rigatos G. Gemcitabine and docetaxel as first-line treatment for advanced urothelial carcinoma: a phase II study. British Journal of Cancer. 2005;92(4):645-650. [pmid: 15685232].
222 Artz A, Stadler WM, Vogelzang NJ, Zimmerman T, Ryan C. A phase II trial of sequential chemotherapy with docetaxel and methotrexate followed by gemcitabine and cisplatin for metastatic urothelial cancer. American Journal of Clinical Oncology. 2005;28(2):109-113. [pmid: 15803001].
223 Hainsworth JD, Meluch AA, Litchy S, et al. Paclitaxel, carboplatin, and gemcitabine in the treatment of patients with advanced transitional cell carcinoma of the urothelium. Cancer. 2005;103(11):2298-2303. [pmid: 15856431].
224 Li J, Juliar B, Yiannoutsos C, et al. Weekly paclitaxel and gemcitabine in advanced transitional-cell carcinoma of the urothelium: a phase II Hoosier Oncology Group study. Journal of Clinical Oncology. 2005;23(6):1185-1191. [pmid: 15718315].
225 Srinivas S, Guardino AE. A nonplatinum combination in metastatic transitional cell carcinoma. American Journal of Clinical Oncology. 2005;28(2):114-118. [pmid: 15803002].
226 Castagneto B, Zai S, Marenco D, et al. Single-agent gemcitabine in previously untreated elderly patients with advanced bladder carcinoma: response to treatment and correlation with the comprehensive geriatric assessment. Oncology. 2004;67(1):27-32. [pmid: 15459492].
227 Kaufman DS, Carducci MA, Kuzel TM, et al. A multi-institutional phase II trial of gemcitabine plus paclitaxel in patients with locally advanced or metastatic urothelial cancer. Urologic Oncology. 2004;22(5):393-397. [pmid: 15464919].
228 Linardou H, Aravantinos G, Efstathiou E, et al. Gemcitabine and carboplatin combination as first-line treatment in elderly patients and those unfit for cisplatin-based chemotherapy with advanced bladder carcinoma: Phase II study of the Hellenic Co-operative Oncology Group. Urology. 2004;64(3):479-484. [pmid: 15351574].
229 Gitlitz BJ, Baker C, Chapman Y, et al. A phase II study of gemcitabine and docetaxel therapy in patients with advanced urothelial carcinoma. Cancer. 2003;98(9):1863-1869. [pmid: 14584068].
230 Mallick JA, Ali SA, Siddiqui N, Fareed A. Impact of Gemcitabine and Cisplatin with radiotherapy in locally advanced or metastatic transitional cell carcinoma of urinary bladder. JPMA - Journal of the Pakistan Medical Association. 2003;53(11):547-552.
231 Turkolmez K, Beduk Y, Baltaci S, Gogus C, Gogus O. Gemcitabine plus vinorelbine chemotherapy in patients with advanced bladder carcinoma who are medically unsuitable for or who have failed cisplatin-based chemotherapy. European Urology. 2003;44(6):682-686. [pmid: 14644120].
232 Albers P, Siener R, Hartlein M, et al. Gemcitabine monotherapy as second-line treatment in cisplatin-refractory transitional cell carcinoma - prognostic factors for response and improvement of quality of life. Onkologie. 2002;25(1):47-52. [pmid: 11893883].
233 Neri B, Doni L, Fulignati C, et al. Gemcitabine plus Epi-doxorubicin as first-line chemotherapy for bladder cancer in advanced or metastatic stage: a phase II. Anticancer Research. 2002;22(5):2981-2984. [pmid: 12530029].
234 Pectasides D, Glotsos J, Bountouroglou N, et al. Weekly chemotherapy with docetaxel, gemcitabine and cisplatin in advanced transitional cell urothelial cancer: a phase II trial. Annals of Oncology. 2002;13(2):243-250. [pmid: 11886001].
235 Ricci S, Galli L, Chioni A, et al. Gemcitabine plus epirubicin in patients with advanced urothelial carcinoma who are not eligible for platinum-based regimens. Cancer. 2002;95(7):1444-1450. [pmid: 12237912].
236 Meluch AA, Greco FA, Burris HA 3rd, et al. Paclitaxel and gemcitabine chemotherapy for advanced transitional-cell carcinoma of the urothelial tract: a phase II trial of the Minnie pearl cancer research network. Journal of Clinical Oncology. 2001;19(12):3018-3024. [pmid: 11408496].
237 Carles J, Nogue M, Domenech M, et al. Carboplatin-gemcitabine treatment of patients with transitional cell carcinoma of the bladder and impaired renal function. Oncology. 2000;59(1):24-27. [pmid: 10895062].
238 Delord JP, Raymond E, Chaouche M, et al. A dose-finding study of gemcitabine and vinorelbine in advanced previously treated malignancies. Annals of Oncology. 2000;11(1):73-79. [pmid: 10690391].
239 Khaled HM, Hamza MR, Mansour O, Gaafar R, Zaghloul MS. A phase II study of gemcitabine plus cisplatin chemotherapy in advanced bilharzial bladder carcinoma. European Journal of Cancer. Suppl 2. 2000;36:34-37. [pmid: 10908847].
240 Lorusso V, Manzione L, De Vita F, Antimi M, Selvaggi FP, De Lena M. Gemcitabine plus cisplatin for advanced transitional cell carcinoma of the urinary tract: a phase II multicenter trial. Journal of Urology. 2000;164(1):53-56. [pmid: 10840423].
241 Moore MJ, Winquist EW, Murray N, et al. Gemcitabine plus cisplatin, an active regimen in advanced urothelial cancer: a phase II trial of the National Cancer Institute of Canada Clinical Trials Group. Journal of Clinical Oncology. 1999;17(9):2876-2881. [pmid: 10561365].
242 Lorusso V, Pollera CF, Antimi M, et al. A phase II study of gemcitabine in patients with transitional cell carcinoma of the urinary tract previously treated with platinum. Italian Co-operative Group on Bladder Cancer. European Journal of Cancer. 1998;34(8):1208-1212. [pmid: 9849481].
243 Moore MJ, Tannock IF, Ernst DS, Huan S, Murray N. Gemcitabine: a promising new agent in the treatment of advanced urothelial cancer. Journal of Clinical Oncology. 1997;15(12):3441-3445. [pmid: 9396395].
244 Stadler WM, Kuzel T, Roth B, Raghavan D, Dorr FA. Phase II study of single-agent gemcitabine in previously untreated patients with metastatic urothelial cancer. Journal of Clinical Oncology. 1997;15(11):3394-3398. [pmid: 9363871].
245 Hussain SA, Stocken DD, Riley P, et al. A phase I/II study of gemcitabine and fractionated cisplatin in an outpatient setting using a 21-day schedule in patients with advanced and metastatic bladder cancer. British Journal of Cancer. 2004;91(5):844-849. [pmid: 15292922].
246 Bellmunt J, Albanell J, Paz-Ares L, et al. Pretreatment prognostic factors for survival in patients with advanced urothelial tumors treated in a phase I/II trial with paclitaxel, cisplatin, and gemcitabine. Cancer. 2002;95(4):751-757. [pmid: 12209718].
247 Sangar VK, McBain CA, Lyons J, et al. Phase I study of conformal radiotherapy with concurrent gemcitabine in locally advanced bladder cancer. International Journal of Radiation Oncology, Biology, Physics. 2005;61(2):420-425.
248 Herman JM, Smith DC, Montie J, et al. Prospective quality-of-life assessment in patients receiving concurrent gemcitabine and radiotherapy as a bladder preservation strategy. Urology. 2004;64(1):69-73. [pmid: 15245938].
249 Kent E, Sandler H, Montie J, et al. Combined-modality therapy with gemcitabine and radiotherapy as a bladder preservation strategy: results of a phase I trial. Journal of Clinical Oncology. 2004;22(13):2540-2545. [pmid: 15226322].
250 Caffo O, Fellin G, Graffer U, et al. Phase I study of gemcitabine and radiotherapy plus cisplatin after transurethral resection as conservative treatment for infiltrating bladder cancer. International Journal of Radiation Oncology, Biology, Physics. 2003;57(5):1310-1316.
251 Culine S, Rebillard X, Iborra F, et al. Gemcitabine and oxaliplatin in advanced transitional cell carcinoma of the urothelium: a pilot study. Anticancer Research. 2003;23(2C):1903-1906. [pmid: 12820476].
252 DiPaola RS, Rubin E, Toppmeyer D, et al. Gemcitabine combined with sequential paclitaxel and carboplatin in patients with urothelial cancers and other advanced malignancies. Medical Science Monitor. 2003;9(2):PI5-P11. [pmid: 12601301].
253 Meliani E, Lapini A, Serni S, Corvino C, Carini M. Gemcitabine plus cisplatin in adjuvant regimen for bladder cancer. Toxicity evaluation. Urologia Internationalis. 2003;71(1):37-40. [pmid: 12845258].
254 Bellmunt J, de Wit R, Albanell J, Baselga J. A feasibility study of carboplatin with fixed dose of gemcitabine in"unfit" patients with advanced bladder cancer. European Journal of Cancer. 2001;37(17):2212-2215. [pmid: 11677109].
255 Bhargava P, Marshall J, Fried K, et al. Phase I and pharmacokinetic study of two sequences of gemcitabine and docetaxel administered weekly to patients with advanced cancer. Cancer Chemotherapy & Pharmacology. 2001;48(2):95-103. [pmid: 11561784].
256 Millikan RE, Plunkett WK, Smith TL, Williams DL, Logothetis CJ. Gemcitabine modulation of alkylator therapy: a phase I trial of escalating gemcitabine added to fixed doses of ifosfamide and doxorubicin. Cancer. 2001;92(1):194-199. [pmid: 11443627].
257 Pollera CF, Ceribelli A, Crecco M, Calabresi F. Weekly gemcitabine in advanced bladder cancer: a preliminary report from a phase I study. Annals of Oncology. 1994;5(2):182-184. [pmid: 8186164].
258 Bamias A, Efstathiou E, Moulopoulos LA, et al. The outcome of elderly patients with advanced urothelial carcinoma after platinum-based combination chemotherapy.[see comment]. Annals of Oncology. 2005;16(2):307-313. [pmid: 15668289].
259 Roychowdhury DF, Hayden A, Liepa AM. Health-related quality-of-life parameters as independent prognostic factors in advanced or metastatic bladder cancer. Journal of Clinical Oncology. 2003;21(4):673-678. [pmid: 12586805].
260 Stadler WM, Hayden A, von der Maase H, et al. Long-term survival in phase II trials of gemcitabine plus cisplatin for advanced transitional cell cancer. Urologic Oncology. 2002;7(4):153-157. [pmid: 12474531].
261 Anonymous. Drugs for cancer. Medical Letter on Drugs & Therapeutics. 2000;42(1087–1088):83-92. [pmid: 10994034].
262 Roth BJ. Chemotherapy for advanced bladder cancer. Seminars in Oncology. 1996;23(5):633-644. [pmid: 8893874].
263 Pfisterer J, Vergote I, Du Bois A, et al. Combination therapy with gemcitabine and carboplatin in recurrent ovarian cancer. International Journal of Gynecological Cancer. Suppl 1. 2005;15:36-41. [pmid: 15839957].
264 Liu F-S, Ho ES-C, Hung M-J, Hwang S-F, Lu C-H, Ke Y-M. Triplet combination of gemcitabine, carboplatin, and paclitaxel in previously treated, relapsed ovarian and peritoneal carcinoma: an experience in Taiwan. Gynecologic Oncology. 2004;94(2):393-397. [pmid: 15297178].
265 Micha JP, Goldstein BH, Rettenmaier MA, et al. Pilot study of outpatient paclitaxel, carboplatin and gemcitabine for advanced stage epithelial ovarian, peritoneal, and fallopian tube cancer. Gynecologic Oncology. 2004;94(3):719-724. [pmid: 15350364].
266 Lund B, Hansen OP, Theilade K, Hansen M, Neijt JP. Phase II study of gemcitabine (2',2'-difluorodeoxycytidine) in previously treated ovarian cancer patients. Journal of the National Cancer Institute. 1994;86(20):1530-1533. [pmid: 7932808].
267 Vasey PA, Atkinson R, Osborne R, et al. SCOTROC 2A: carboplatin followed by docetaxel or docetaxel-gemcitabine as first-line chemotherapy for ovarian cancer. British Journal of Cancer. 2006;94(1):62-68. [pmid: 16404361].
268 du Bois A, Belau A, Wagner U, et al. A phase II study of paclitaxel, carboplatin, and gemcitabine in previously untreated patients with epithelial ovarian cancer FIGO stage IC-IV (AGO-OVAR protocol OVAR-8). Gynecologic Oncology. 2005;96(2):444-451. [pmid: 15661234].
269 Ferrandina G, Paris I, Ludovisi M, et al. Gemcitabine and liposomal doxorubicin in the salvage treatment of ovarian cancer: updated results and long-term survival. Gynecologic Oncology. 2005;98(2):267-273. [pmid: 15975643].
270 Gupta SK, John S, Naik R, et al. A multicenter phase II study of gemcitabine, paclitaxel, and cisplatin in chemonaive advanced ovarian cancer. Gynecologic Oncology. 2005;98(1):134-140. [pmid: 15894360].
271 Kose MF, Sufliarsky J, Beslija S, et al. A phase II study of gemcitabine plus carboplatin in platinum-sensitive, recurrent ovarian carcinoma. Gynecologic Oncology. 2005;96(2):374-380. [pmid: 15661224].
272 Garcia AA, O'Meara A, Bahador A, et al. Phase II study of gemcitabine and weekly paclitaxel in recurrent platinum-resistant ovarian cancer. Gynecologic Oncology. 2004;93(2):493-498. [pmid: 15099968].
273 Harries M, Moss C, Perren T, et al. A phase II feasibility study of carboplatin followed by sequential weekly paclitaxel and gemcitabine as first-line treatment for ovarian cancer. British Journal of Cancer. 2004;91(4):627-632. [pmid: 15238984].
274 Papadimitriou CA, Fountzilas G, Aravantinos G, et al. Second-line chemotherapy with gemcitabine and carboplatin in paclitaxel-pretreated, platinum-sensitive ovarian cancer patients. A Hellenic Cooperative Oncology Group Study. Gynecologic Oncology. 2004;92(1):152-159. [pmid: 14751151].
275 Bauknecht T, Hefti A, Morack G, et al. Gemcitabine combined with cisplatin as first-line treatment in patients 60 years or older with epithelial ovarian cancer: a phase II study.[see comment]. International Journal of Gynecological Cancer. 2003;13(2):130-137. [pmid: 12657112].
276 Belpomme D, Krakowski I, Beauduin M, et al. Gemcitabine combined with cisplatin as first-line treatment in patients with epithelial ovarian cancer: a phase II study. Gynecologic Oncology. 2003;91(1):32-38. [pmid: 14529659].
277 D'Agostino G, Ferrandina G, Ludovisi M, et al. Phase II study of liposomal doxorubicin and gemcitabine in the salvage treatment of ovarian cancer. British Journal of Cancer. 2003;89(7):1180-1184. [pmid: 14520442].
278 D'Agostino G, Amant F, Berteloot P, Scambia G, Vergote I. Phase II study of gemcitabine in recurrent platinum-and paclitaxel-resistant ovarian cancer. Gynecologic Oncology. 2003;88(3):266-269. [pmid: 12648573].
279 Markman M, Webster K, Zanotti K, Kulp B, Peterson G, Belinson J. Phase 2 trial of single-agent gemcitabine in platinum-paclitaxel refractory ovarian cancer. Gynecologic Oncology. 2003;90(3):593-596. [pmid: 13678730].
280 Nagourney RA, Brewer CA, Radecki S, et al. Phase II trial of gemcitabine plus cisplatin repeating doublet therapy in previously treated, relapsed ovarian cancer patients. Gynecologic Oncology. 2003;88(1):35-39. [pmid: 12504624].
281 Nogue M, Cirera L, Arcusa A, et al. Phase II study of gemcitabine and cisplatin in chemonaive patients with advanced epithelial ovarian cancer. Anti-Cancer Drugs. 2002;13(8):839-845. [pmid: 12394269].
282 Sehouli J, Stengel D, Oskay G, et al. A phase II study of topotecan plus gemcitabine in the treatment of patients with relapsed ovarian cancer after failure of first-line chemotherapy. Annals of Oncology. 2002;13(11):1749-1755. [pmid: 12419747].
283 Underhill CR, Parnis FX, Highley MS, et al. Multicenter phase II study of gemcitabine in previously untreated patients with advanced epithelial ovarian cancer. Anti-Cancer Drugs. 2001;12(8):647-652. [pmid: 11604551].
284 Silver DF, Piver MS. Gemcitabine salvage chemotherapy for patients with gynecologic malignancies of the ovary, fallopian tube, and peritoneum. American Journal of Clinical Oncology. 1999;22(5):450-452. [pmid: 10521056].
285 von Minckwitz G, Bauknecht T, Visseren-Grul CM, Neijt JP. Phase II study of gemcitabine in ovarian cancer. Annals of Oncology. 1999;10(7):853-855. [pmid: 10470434].
286 Friedlander M, Millward MJ, Bell D, et al. A phase II study of gemcitabine in platinum pre-treated patients with advanced epithelial ovarian cancer.[see comment]. Annals of Oncology. 1998;9(12):1343-1345. [pmid: 9932166].
287 Lund B, Hansen OP, Neijt JP, Theilade K, Hansen M. Phase II study of gemcitabine in previously platinum-treated ovarian cancer patients. Anti-Cancer Drugs. Suppl 6. 1995;6:61-62. [pmid: 8718427].
288 Barlow C, Nystrom M, Oesterling C, Fennell D, Ismay J, Gallagher C. Dose intense triplet chemotherapy with gemcitabine, carboplatin, paclitaxel with peripheral blood progenitor cell support for six cycles in advanced epithelial ovarian cancer. British Journal of Cancer. 2004;90(7):1318-1322. [pmid: 15054448].
289 Sabbatini P, Aghajanian C, Leitao M, et al. Intraperitoneal cisplatin with intraperitoneal gemcitabine in patients with epithelial ovarian cancer: results of a phase I/II Trial. Clinical Cancer Research. 2004;10(9):2962-2967. [pmid: 15131031].
290 Greggi S, Salerno MG, D'Agostino G, et al. Topotecan and gemcitabine in platinum/paclitaxel-resistant ovarian cancer. Oncology. 2001;60(1):19-23. [pmid: 11150903].
291 Look KY, Bookman MA, Schol J, et al. Phase I feasibility trial of carboplatin, paclitaxel, and gemcitabine in patients with previously untreated epithelial ovarian or primary peritoneal cancer: a Gynecologic Oncology Group study. Gynecologic Oncology. 2004;92(1):93-100. [pmid: 14751144].
292 Sehouli J, Stengel D, Oskay G, Blohmer J, Kaubitzsch S, Lichtenegger W. A new therapeutical approach: topotecan plus gemcitabine in the treatment of patients with relapsed ovarian cancer after failure of first-line chemotherapy with paclitaxel and platinum. Journal of Obstetrics & Gynaecology Research. 2003;29(3):123-131. [pmid: 12841693].
293 D'Agostino G, Ferrandina G, Garganese G, et al. Phase I study of gemcitabine and liposomal doxorubicin in relapsed ovarian cancer. Oncology. 2002;62(2):110-114. [pmid: 11914595].
294 Fracasso PM, Rader JS, Govindan R, et al. Phase I study of rubitecan and gemcitabine in patients with advanced malignancies. Annals of Oncology. 2002;13(11):1819-1825. [pmid: 12419757].
295 du Bois A, Luck HJ, Pfisterer J, et al. Second-line carboplatin and gemcitabine in platinum sensitive ovarian cancer--a dose-finding study by the Arbeitsgemeinschaft Gynakologische Onkologie (AGO) Ovarian Cancer Study Group. Annals of Oncology. 2001;12(8):1115-1120. [pmid: 11583193].
296 Iaffaioli RV, Tortoriello A, Santangelo M, et al. Phase I dose escalation study of gemcitabine and paclitaxel plus colony-stimulating factors in previously treated patients with advanced breast and ovarian cancer. Clinical Oncology (Royal College of Radiologists). 2000;12(4):251-255.
297 Pignata S, Varriale E, Casella G, et al. A phase I study of gemcitabine and epirubicin for the treatment of platinum-resistant or refractory advanced ovarian cancer. Annals of Oncology. 2000;11(5):613-616. [pmid: 10907958].
298 Shapiro JD, Millward MJ, Rischin D, et al. Activity of gemcitabine in patients with advanced ovarian cancer: responses seen following platinum and paclitaxel. Gynecologic Oncology. 1996;63(1):89-93. [pmid: 8898175].
299 Rose PG. Gemcitabine reverses platinum resistance in platinum-resistant ovarian and peritoneal carcinoma. International Journal of Gynecological Cancer. 2005;15 Suppl 1:18-22. [pmid: 15839954].
300 Geisler JP, Schraith DF, Manahan KJ, Sorosky JI. Gemcitabine associated vasculitis leading to necrotizing enterocolitis and death in women undergoing primary treatment for epithelial ovarian/peritoneal cancer. Gynecologic Oncology. 2004;92(2):705-707. [pmid: 14766271].
301 Prasad M, Ben-Porat L, Hoppe B, et al. Costs of treatment and outcomes associated with second-line therapy and greater for relapsed ovarian cancer. Gynecologic Oncology. 2004;93(1):223-228. [pmid: 15047240].
302 Tewari D, Monk BJ, Hunter M, Falkner CA, Burger RA. Gemcitabine and cisplatin chemotherapy is an active combination in the treatment of platinum-resistant ovarian and peritoneal carcinoma. Investigational New Drugs. 2004;22(4):475-480. [pmid: 15292718].
303 Villella J, Marchetti D, Odunsi K, Rodabaugh K, Driscoll DL, Lele S. Response of combination platinum and gemcitabine chemotherapy for recurrent epithelial ovarian carcinoma. Gynecologic Oncology. 2004;95(3):539-545. [pmid: 15581960].
304 Bilgin T, Ozalp S, Yalcin OT, Zorlu G, Vardar MA, Ozerkan K. Efficacy of gemcitabine in heavily pretreated advanced ovarian cancer patients. European Journal of Gynaecological Oncology. 2003;24(2):169-170. [pmid: 12701971].
305 National Cancer Institute. Bladder Cancer. National Cancer Institute. 2001.
306 Gerson R, Serrano A, Dolengevich H, Villalobos A. [Chemotherapy in germinal and epithelial ovarian cancer]. Ginecologia y Obstetricia de Mexico. 2000;68:165-170. [pmid: 10824448].
307 Eisenhauer EA, Vermorken JB, van Glabbeke M. Predictors of response to subsequent chemotherapy in platinum pretreated ovarian cancer: a multivariate analysis of 704 patients [seecomments][see comment]. Annals of Oncology. 1997;8(10):963-968. [pmid: 9402168].
308 Kaufmann M, von Minckwitz G. Gemcitabine in ovarian cancer: an overview of safety and efficacy. European Journal of Cancer. Suppl 1. 1997;33:S31-S33. [pmid: 9166098].
309 Pedersen AG. Phase I studies of gemcitabine combined with carboplatin or paclitaxel. Seminars in Oncology. 1997;24(2 Suppl 7):S7-64-S7-68. [pmid: 9194483].
310 Martin C, Lund B, Anderson H, Thatcher N. Gemcitabine: once-weekly schedule active and better tolerated than twice-weekly schedule. Anti-Cancer Drugs. 1996;7(3):351-357. [pmid: 8792011].
311 Byrd JC, Peterson BL, Morrison VA, et al. Randomized phase 2 study of fludarabine with concurrent versus sequential treatment with rituximab in symptomatic, untreated patients with B-cell chronic lymphocytic leukemia: results from Cancer and Leukemia Group B 9712 (CALGB 9712).[see comment]. Blood. 2003;101(1):6-14. [pmid: 12393429].
312 Tothova E, Kafkova A, Guman T, Stecova N, Fricova M. Efficiency of in vivo purging with autologous stem cell transplantation and monoclonal antibody in B-cell lymphomas. Neoplasma. 2003;50(1):22-25. [pmid: 12687274].
313 Del Poeta G, Del Principe MI, Consalvo MAI, et al. The addition of rituximab to fludarabine improves clinical outcome in untreated patients with ZAP-70-negative chronic lymphocytic leukemia. Cancer. 2005;104(12):2743-2752. [pmid: 16284990].
314 Keating MJ, O'Brien S, Albitar M, et al. Early results of a chemoimmunotherapy regimen of fludarabine, cyclophosphamide, and rituximab as initial therapy for chronic lymphocytic leukemia.[see comment]. Journal of Clinical Oncology. 2005;23(18):4079-4088. [pmid: 15767648].
315 Khouri IF, Lee M-S, Saliba RM, et al. Nonablative allogeneic stem cell transplantation for chronic lymphocytic leukemia: impact of rituximab on immunomodulation and survival. Experimental Hematology. 2004;32(1):28-35. [pmid: 14725898].
316 Tsiara SN, Kapsali HD, Chaidos A, Christou L, Bourantas KL. Treatment of resistant/relapsing chronic lymphocytic leukemia with a combination regimen containing deoxycoformycin and rituximab. Acta Haematologica. 2004;111(4):185-188. [pmid: 15153709].
317 Hainsworth JD, Litchy S, Barton JH, et al. Single-agent rituximab as first-line and maintenance treatment for patients with chronic lymphocytic leukemia or small lymphocytic lymphoma: a phase II trial of the Minnie Pearl Cancer Research Network. Journal of Clinical Oncology. 2003;21(9):1746-1751. [pmid: 12721250].
318 Tsimberidou AM, Kantarjian HM, Cortes J, et al. Fractionated cyclophosphamide, vincristine, liposomal daunorubicin, and dexamethasone plus rituximab and granulocyte-macrophage-colony stimulating factor (GM-CSF) alternating with methotrexate and cytarabine plus rituximab and GM-CSF in patients with Richter syndrome or fludarabine-refractory chronic lymphocytic leukemia. Cancer. 2003;97(7):1711-1720. [pmid: 12655528].
319 Itala M, Geisler CH, Kimby E, et al. Standard-dose anti-CD20 antibody rituximab has efficacy in chronic lymphocytic leukaemia: results from a Nordic multicentre study. European Journal of Haematology. 2002;69(3):129-134. [pmid: 12406005].
320 Schulz H, Klein SK, Rehwald U, et al. Phase 2 study of a combined immunochemotherapy using rituximab and fludarabine in patients with chronic lymphocytic leukemia. Blood. 2002;100(9):3115-3120. [pmid: 12384407].
321 Huhn D, von Schilling C, Wilhelm M, et al. Rituximab therapy of patients with B-cell chronic lymphocytic leukemia.[see comment]. Blood. 2001;98(5):1326-1331. [pmid: 11520778].
322 Hainsworth JD, Burris HA 3rd, Morrissey LH, et al. Rituximab monoclonal antibody as initial systemic therapy for patients with low-grade non-Hodgkin lymphoma. Blood. 2000;95(10):3052-3056. [pmid: 10807768].
323 Ladetto M, Bergui L, Ricca I, Campana S, Pileri A, Tarella C. Rituximab anti-CD20 monoclonal antibody induces marked but transient reductions of peripheral blood lymphocytes in chronic lymphocytic leukaemia patients. Medical Oncology. 2000;17(3):203-210. [pmid: 10962531].
324 Nguyen DT, Amess JA, Doughty H, Hendry L, Diamond LW. IDEC-C2B8 anti-CD20 (rituximab) immunotherapy in patients with low-grade non-Hodgkin's lymphoma and lymphoproliferative disorders: evaluation of response on 48 patients. European Journal of Haematology. 1999;62(2):76-82. [pmid: 10052709].
325 Wierda W, O'Brien S, Wen S, et al. Chemoimmunotherapy with fludarabine, cyclophosphamide, and rituximab for relapsed and refractory chronic lymphocytic leukemia.[see comment]. Journal of Clinical Oncology. 2005;23(18):4070-4078. [pmid: 15767647].
326 Weide R, Pandorf A, Heymanns J, Koppler H. Bendamustine/Mitoxantrone/Rituximab (BMR): a very effective, well tolerated outpatient chemoimmunotherapy for relapsed and refractory CD20-positive indolent malignancies. Final results of a pilot study. Leukemia & Lymphoma. 2004;45(12):2445-2449. [pmid: 15621757].
327 Savage DG, Cohen NS, Hesdorffer CS, et al. Combined fludarabine and rituximab for low grade lymphoma and chronic lymphocytic leukemia. Leukemia & Lymphoma. 2003;44(3):477-481. [pmid: 12688318].
328 Byrd JC, Murphy T, Howard RS, et al. Rituximab using a thrice weekly dosing schedule in B-cell chronic lymphocytic leukemia and small lymphocytic lymphoma demonstrates clinical activity and acceptable toxicity. Journal of Clinical Oncology. 2001;19(8):2153-2164. [pmid: 11304767].
329 Winkler U, Jensen M, Manzke O, Schulz H, Diehl V, Engert A. Cytokine-release syndrome in patients with B-cell chronic lymphocytic leukemia and high lymphocyte counts after treatment with an anti-CD20 monoclonal antibody (rituximab, IDEC-C2B8). Blood. 1999;94(7):2217-2224. [pmid: 10498591].
330 Perz J, Topaly J, Fruehauf S, Hensel M, Ho AD. Level of CD 20-expression and efficacy of rituximab treatment in patients with resistant or relapsing B-cell prolymphocytic leukemia and B-cell chronic lymphocytic leukemia. Leukemia & Lymphoma. 2002;43(1):149-151. [pmid: 11908720].
331 O'Brien SM, Kantarjian H, Thomas DA, et al. Rituximab dose-escalation trial in chronic lymphocytic leukemia. Journal of Clinical Oncology. 2001;19(8):2165-2170. [pmid: 11304768].
332 Keating M, O'Brien S. High-dose rituximab therapy in chronic lymphocytic leukemia. Seminars in Oncology. 2000;27(6 Suppl 12):86-90. [pmid: 11226005].
333 Narayan H, Bandyopadhyay D, Schmidt K, et al. Successful treatment of a patient with chronic lymphocytic leukaemia (CLL) presenting with bony metastases with aggressive antibody and chemotherapy. Clinical & Laboratory Haematology. 2005;27(6):405-408. [pmid: 16307545].
334 Robak E, Biernat W, Krykowski E, Jeziorski A, Robak T. Merkel cell carcinoma in a patient with B-cell chronic lymphocytic leukemia treated with cladribine and rituximab. Leukemia & Lymphoma. 2005;46(6):909-914. [pmid: 16019537].
335 Watanabe N, Takahashi T, Sugimoto N, et al. Excellent response of chemotherapy-resistant B-cell-type chronic lymphocytic leukemia with meningeal involvement to rituximab. International Journal of Clinical Oncology. 2005;10(5):357-361. [pmid: 16247665].
336 Nabhan C, Patton D, Gordon LI, et al. A pilot trial of rituximab and alemtuzumab combination therapy in patients with relapsed and/or refractory chronic lymphocytic leukemia (CLL). Leukemia & Lymphoma. 2004;45(11):2269-2273. [pmid: 15512816].
337 Jilani I, O'Brien S, Manshuri T, et al. Transient down-modulation of CD20 by rituximab in patients with chronic lymphocytic leukemia.[see comment]. Blood. 2003;102(10):3514-3520. [pmid: 12893761].
338 Cohen Y, Da'as N, Libster D, Amir G, Berrebi A, Polliack A. Large-cell transformation of chronic lymphocytic leukemia and follicular lymphoma during or soon after treatment with fludarabine-rituximab-containing regimens: natural history- or therapy-related complication?. European Journal of Haematology. 2002;68(2):80-83. [pmid: 12038452].
339 Kanelli S, Ansell SM, Habermann TM, Inwards DJ, Tuinstra N, Witzig TE. Rituximab toxicity in patients with peripheral blood malignant B-cell lymphocytosis. Leukemia & Lymphoma. 2001;42(6):1329-1337. [pmid: 11911416].
340 Seipelt G, Bohme A, Koschmieder S, Hoelzer D. Effective treatment with rituximab in a patient with refractory prolymphocytoid transformed B-chronic lymphocytic leukemia and Evans syndrome. Annals of Hematology. 2001;80(3):170-173. [pmid: 11320903].
341 Syrigos KN, Pliarchopoulou K, Harrington KJ. The development of monoclonal antibody therapy in leukemias. Hybridoma. 2001;20(3):145-148. [pmid: 11461662].
342 Weiss MA. Novel treatment strategies in chronic lymphocytic leukemia. Current Oncology Reports. 2001;3(3):217-222. [pmid: 11296131].
343 Herold M, Schulze A, Hartwig K, Anger G. Successful treatment and re-treatment of resistant B-cell chronic lymphocytic leukemia with the monoclonal anti-CD 20 antibody rituximab. Annals of Hematology. 2000;79(6):332-335. [pmid: 10901614].
344 Schulz H, Winkler U, Staak J, Engert A. The monoclonal antibodies Campath-1H and Rituximab in the therapy of chronic lymphocytic leukemia. Onkologie. 2000;23(6):526-532. [pmid: 11441256].
345 Byrd JC, Waselenko JK, Maneatis TJ, et al. Rituximab therapy in hematologic malignancy patients with circulating blood tumor cells: association with increased infusion-related side effects and rapid blood tumor clearance. Journal of Clinical Oncology. 1999;17(3):791-795. [pmid: 10071268].
346 Lim LC, Koh LP, Tan P. Fatal cytokine release syndrome with chimeric anti-CD20 monoclonal antibody rituximab in a 71-year-old patient with chronic lymphocytic leukemia. Journal of Clinical Oncology. 1999;17(6):1962-1963. [pmid: 10561242].
347 Yang H, Rosove MH, Figlin RA. Tumor lysis syndrome occurring after the administration of rituximab in lymphoproliferative disorders: high-grade non-Hodgkin's lymphoma and chronic lymphocytic leukemia. American Journal of Hematology. 1999;62(4):247-250. [pmid: 10589082].
348 Soulieres D, Senzer NN, Vokes EE, Hidalgo M, Agarwala SS, Siu LL. Multicenter phase II study of erlotinib, an oral epidermal growth factor receptor tyrosine kinase inhibitor, in patients with recurrent or metastatic squamous cell cancer of the head and neck. Journal of Clinical Oncology. 2004;22(1):77-85. [pmid: 14701768].
349 Adjei A. Epidermal growth factor receptor tyrosine kinase inhibitors in cancer therapy. [citation per DRUGDEX, unable to confirm]. Drug Future. 2001;26(11):1087.
350 Ciardiello F, Tortora G. A novel approach in the treatment of cancer: targeting the epidermal growth factor receptor. Clinical Cancer Research. 2001;7(10):2958-2970. [pmid: 11595683].
351 Iannitti D, Dipetrillo T, Akerman P, et al. Erlotinib and chemoradiation followed by maintenance erlotinib for locally advanced pancreatic cancer: a phase I study. American Journal of Clinical Oncology. 2005;28(6):570-575. [pmid: 16317266].
352 McBride G. Researchers optimistic about targeted drugs for pancreatic cancer. Journal of the National Cancer Institute. 2004;96(21):1570-1572. [pmid: 15523082].
353 Stroup D, Berlin J, Morton S, et al. Meta-analysis of observational studies in epidemiology: A proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. 2000;283(15):2008-2012. [pmid: 10789670].