# Appendices

A Search Strategies

B Evidence Tables