# Results

The search strategy yielded 418 articles. The selection process is described below:

The 158 included reports comprised 69 full reports and abstract-only publications cited in Tables 1a–1d, as well as 36 full reports cited in the text of this report. Study designs included one published phase III controlled clinical trial with five sub-studies. The exact number of unique phase II uncontrolled clinical trials is difficult to establish, as many authors presented data from the same groups of subjects in multiple reports. By best assessment there are approximately 30 individual phase II trials presented here. All of the adverse events data were derived from the phase II and III clinical trials that were published in full reports, with the exception of four additional individual adverse event reports (two full-text articles and two abstracts).

Quality of the studies varied by outcome category (Tables 1a–1d and Appendix B). The main imatinib efficacy studies published in full were of high quality. Quality, in general, was lower for predictor studies, consistent with these more commonly being written as basic science reports with minor clinical correlations. The other group of lower quality reports was emerging reports, especially those evaluating imatinib after stem cell transplant and in the heavily treated setting.

Table 1a Details of included studies–Part 1 Imatinib efficacy studies

Study # | First Author, Year | Trial Phase | Imatinib dose per day (mg) | Comparator | Quality | Comments
Chronic phase–newly diagnosed
1 | O’Brien, Guilhot, et al,, 2003 59 | III | 400 | IFN + Ara-C | 5/5 | Main results from the IRIS phase III trial
1 | Branford, 2003^33^ | | | | 5/6 | IRIS sub-study–molecular responses
1 | Hughes, 2003^11^ | | | | 6/6 | IRIS sub-study–molecular responses
1 | Hahn, 2003^60, 61^ | | | | 5/5 | IRIS sub-study–QOL (on a separate efficacy–QOL table)
1 | *Guilhot, 2004^62^ | | | | * | Follow up data
1 | *Branford, 2004^32^ | | | | * | Follow up data
2 | Karntarjian, Cortes, et al., 2003^63^ | II | 400 | Historical controls | 6/6 | Main results of phase II trial
3 | Karntarjian, Talpaz, et al., 2004^12^ | II | 800 | Historical controls | 5/5 | Main results of phase II trial
2&3 | Kantarjian, O’Brien, 2004^44^ | II | 400–800 | Historical controls | 3/6 | Includes patients from another both studies above
2&3 | *Cortes, Talpaz, OBrien, Giles, et al., 2004^64^ | II | 400–800 | | * | Compares 400 & 800 mg doses
4 | *Hughes, 2004^65^ | II | 600–800 | Compared to IRIS experience | *
Chronic phase–interferon resistant or refractory
5 | Druker, Talpaz, et al., 2001^66^ | I/II | 25–1000 | | 4/5 | Main results of initial STI571 phase I/II
5 | Braziel, 2002^67^ | | | | 3/6 | Druker sub-study - response predictors
6 | Kantarjian, Sawyers, 2002^2^ | II | 400–800 | | 6/6 | Main results of phase II trial
6 | Marin, Marktel, Szydlo, et al., 2003^68^ | | | Historical controls | 5/5 | Survival follow up
7 | Cortes, Giles, et al, 2003^69^ | II | 800 | | 3/5
6&8 | Karntarjian, Talpaz, et al., 2002^70^ | II | 400–800 | | 5/5 | Some patients from the phase II trial plus expanded access
6,8,&9 | Karntarjian, Talpaz, et al., 2003^71^ | II | 400–800 | | 3/6 | Some patients from the phase II trial plus expanded access–evaluation of higher dose I for pts resistant to 400 mg
6,8,&9 | Kantarjian, O’Brien, 2004^44^ | II | 400–800 | Historical controls | 5/6 | Includes patients presented in two studies
6&8 | Karntarjian, Cortes, et al., 2004^72^ | II | 400–800 | Historical controls | 5/6 | Includes patients presented in two studies; survival follow up
10 | Le Coutre, 2003^73^ | II | 400 | | 4/5 | Part of expanded access program population
11 | Marin, Goldman, et al., 2003^74^ | II | 600–1000 | | 1/5 | Evaluation of higher dose I for pts resistant to 400 mg
12 | Marin, Marktel, Bua, et al., 2003^75^ | II | 200–800 | | 2/5
13 | Rosti, 200^48^ | II | 400 | | 4/5
14 | *Pasquini, 2004^76^ | Unclear | 400–600 | | * | QOL on I (see QOL table)
Chronic phase –previous stem cell transplant/heavily pretreated
15 | Cervantes, 2003^37^ | II | 400 | Prior auto SCT vs. IFN resistant/intolerant | 3/6 | Autologous SCT
16 | Fischer, 2002^77^ | II | 400 | | 1/6 | Autologous SCT
17 | Kantarjian, O’Brien, et al., 2002^78^ | II | 400–1000 | | 3/6 | Allogeneic SCT
18 | O’Brien, Giles, et al., 2003^79^ | II | Not stated | | 3/5 | Prior IFN, Ara C, and homoharringtonine +/− allogeneic SCT
19 | *Hess, 2004^80^ | II | 400 | | * | Allogeneic SCT
20 | *Corsetti, 2004^81^ | II | 400–400 | | * | Autologous SCT
Mixed phases
FDA Approval | Cohen, 2002^82^ | I II | 25–1000 400–600 | | 5/6 | FDA Approval summary
21 | *Silver, 2004^83^ | II | 400–600 | | * | 4 yr follow up on three studies
22 | Olavarria, 2003^84^ | II | 400–600 | | 4/6 | All relapsed after allogeneic SCT; all phases
23 | Lahaye, 2005^85^ | II | 400–600 | | 5/6 | 4.5 yr follow up
24 | *Deshmukh, 2004^86^ | II | Not stated | | * | All phases, conducted in India
Accelerated phase
25 | Talpaz, 2002^87^ | II | 400–800 | | 5/6
25 | * Cortes, Talpaz, OBrien, Gracia-Manero, et al., 2004^88^ | | | | * | Followup abstract
Blastic phase/blast crisis
26 | Druker, Sawyers, et al., 2001^89^ | I/II | 300–1000 | | 5/6
27 | Kantarjian, Cortes, 2002^90^ | I/II | 300–1000 | | 5/6
28 | Sawyers, 2002^3^ | II | 400–800 | | 5/6
29 | Sureda, 2003^4^ | II | 600 | | 4/5
Imatinib efficacy/other
30 | Gardembas, 2003^38^ | II | 400 (w/ Ara-C SQ 20 mg/m^2^/d on d15-28) | | 5/5 | Combination=safe
31 | Baccarani, 2004^91^ | II | 400 (w/ Peg-IFN at 50–150 mcg/wk) | | 4/5 | Combination=safe

* Presented as peer-reviewed abstract only.

Abbreviations: Ara-C=cytarabine; I=imatinib; IFN=interferon; pts=patients; QOL=quality of life; Retro=retrospective; SCT=stem cell transplant

Table 1b Details of included studies–Part 2 Studies with additional adverse event/harm data not already presented in the efficacy studies

First Author, Year | Trial Phase | Imatinib dose per day (mg) | Quality | Comments
Adverse events/harm only data presented
Drummond, 2003^92^ | | CP=400 AP= 600 BC=600 | 2/5 | Skin rash
Steegman, 2003^93^ | II | 100–400 | 4/5 | Hypogammaglobulinemaia
Valeyrie, 2003^94^ | II | 100–800 | 3/5 | Cutaneous reactions
*Al-Ali, 2004^95^ | II | Not stated | * | Creatinine kinase levels

* Presented as peer-reviewed abstract only.

Table 1c Details of included studies–Part 3 Studies with information about molecular predictors

First Author, Year | Trial Phase | Imatinib dose per day (mg) | Comparator | Quality | Comments
[underlined: Molecular predictors: Group 1A—DNA factors at the start of imatinib therapy]
Cortes, Talpaz, et al., 200^31^ | II | 400–600 | | 6/6 | % Ph+ metaphases @ start of therapy
Kantarjian, Sawyers, et al., 2002^2^ | II | 400 | | 6/6 | % Ph+ metaphases @ start of therapy
Marin, Goldman, et al., 2003^74^ | II | 600–1000 | | 1/5 | % Ph+ metaphases @ start of therapy
Marin, Marktel, Bua, et al., 2003^75^ | II | 200–800 | | 2/5 | % Ph+ metaphases @ start of therapy
O’Dwyer, 2004^96^ | II | >300 | | 2/5 | % Ph+ metaphases @ start of therapy
Braziel, 2002^67^ | | 300–600 | | 3/6 | Complex cytogenetics
Kantarjian, Cortes, 2002^90^ | I/II | 300–1000 | | 5/6 | Complex cytogenetics
Sawyers, 2002^3^ | II | 400–800 | | 5/6 | Complex cytogenetics
Sureda, 2003^4^ | II | 600 | | 4/5 | Complex cytogenetics
Talpaz, 2002^87^ | II | 400–800 | | 5/6 | Complex cytogenetics
Cortes, Talpaz, et al., 2003^1^ | II | 400–600 | | 6/6 | Cytogenetic clonal evolution
El-Zimaity, 2004^97^ | Retro | Unclear | | 3/6 | Cytogenetic clonal evolution
Kantarjian, Sawyers, et al., 2002^2^ | II | 400 | | 6/6 | Cytogenetic clonal evolution
Karntarjian, Talpaz, et al., 2002^70^ | II | 400–800 | | 5/5 | Cytogenetic clonal evolution
Kantarjian, O’Brien, et al., 2004^44^ | II | 400–800 | Historical controls | 5/6 | Cytogenetic clonal evolution
Kantarjian, O’Brien, et al., 2003^98^ | II | 400–800 | Historical controls | 3/6 | Cytogenetic clonal evolution
Karntarjian, Cortes, et al., 2004^72^ | II | 400–800 | Historical controls | 5/6 | Cytogenetic clonal evolution
Marin, Marktel, Bua, et al., 2003^75^ | II | 200–800 | | 2/5 | Cytogenetic clonal evolution
Marktel, 2003^99^ | II | 400–800 | | 5/6 | Cytogenetic clonal evolution
O’Dwyer, 2004^96^ | II | >300 | | 2/5 | Cytogenetic clonal evolution
*Marin, 2004^100^ | Unclear | 400 | | | CD34+ cells in the bone marrow
*Elliott, 2004^101^ | Unclear | 400 | | * | CD34+ cells in the bone marrow
El-Zimaity, 2004^97^ | Retro | Unclear | | 3/6 | Variant Ph translocations
Huntly, 2003^51^ | II | Not stated | | 2/6 | Chromosome 9 deletions
Lange, 2003^102^ | Retro | 600 | | 4/6 | Genes related to apoptosis and drug resistance in leukemia cells
McLean103 | III | 400 | IFN+Ara-C | 5/6 | Genomic microarrays
[underlined: Molecular predictors: Group 1B—DNA factors monitored during imatinib therapy]
Marin, Marktel, Szydlo, et al., 2003^68^ | II | 400–800 | Historical controls | 5/5 | Cytogenetic response to imatinib
O’Dwyer, 2004^96^ | II | >300 | | 2/5 | Cytogenetic response to imatinib
Rosti, 2004^8^ | II | 400 | | 4/5 | Cytogenetic response to imatinib
*Silver, 2004^83^ | II | 400–600 | | * | Cytogenetic response to imatinib
Karntarjian, Cortes, et al., 2004^72^ | II | 400–800 | Historical controls | 5/6 | Cytogenetic response to imatinib
*Guilhot, 2004^62^ | III | 400 | IFN+Ara-C | * | Cytogenetic response to imatinib
Marin, Marktel, Bua, et al., 2003^75^ | II | 200–800 | | 2/5 | Cytogenetic response to imatinib
*Marin, 2004^100^ | Unclear | 400 | | | Change in CD34+ cells in the bone marrow
Marin, Marktel, Szydlo, et al., 2003^68^ | II | 400–800 | Historical controls | 5/5 | Cytogenetic response to imatinib
[underlined: Molecular predictors: Group 2–Production of the RNA message]
Paschka, 2003^10^ | II | 400–800 | | 4/6 | Molecular response as a marker of tumor response
Müller, 2003^104^ | III | 400 | IFN+Ara-C | 5/6 | Molecular response as a marker of tumor response
Hughes 2003^11^ | III | 400 | IFN+Ara-C | 6/6 | Molecular response as a marker of tumor response
Merx, 2002^105^ | II | 400–800 | | 5/5 | Molecular response as a marker of tumor response
Rosti, 2004^8^ | II | 400 | | 4/5 | Molecular response as a marker of tumor response
Stentoft, 2001^7^ | II | 400–600 | | 4/5 | Molecular response as a marker of tumor response
Wu, 2002^6^ | II | 400–600 | | 3/5 | Molecular response as a marker of tumor response
*Cortes, Talpaz, OBrien, Giles, et al., 2004^5^ | II | Not stated | | * | Molecular response as a marker of tumor response
Moravcova, 2004^9^ | II | 400–600 | | 3/6 | Molecular response as a marker of tumor response
Karntarjian, Talpaz, et al., 2004^12^ | II | 800 | Historical controls | 5/5 | Molecular response as a marker of tumor response
Müller, 2003^104^ | III | 400 | IFN+Ara-C | 5/6 | Prognostic value of baseline transcript levels
Hochhaus, 2002^55^ | II | 400–600 | | 5/6 | Prognostic value of baseline transcript levels
Wu, 2002^6^ | II | 400–600 | | 3/5 | Prognostic value of baseline transcript levels
Branford, 2003^33^ | III | 400 | IFN+Ara-C | 5/6 | Prognostic value of transcript trends while on imatinib
Hughes 2003^11^ | III | 400 | IFN+Ara-C | 6/6 | Prognostic value of transcript trends while on imatinib
Rosti, 2004^8^ | II | 400 | | 4/5 | Prognostic value of transcript trends while on imatinib
Müller, 2003^104^ | III | 400 | IFN+Ara-C | 5/6 | Prognostic value of transcript trends while on imatinib
*Müller, 2004^106^ | III | 400 | | * | Prognostic value of transcript trends while on imatinib
*Branford, 2004^32^ | III | 400 | | * | Prognostic value of transcript trends while on imatinib
*Cortes, Talpaz, OBrien, Giles, et al., 2004^5^ | II | Not stated | | * | Prognostic value of transcript trends while on imatinib
*Press, 2004^107^ | II | Not stated | | * | Prognostic value of transcript trends while on imatinib
Wang, 2003^48^ | II | Not stated | | 2/5 | Prognostic value of transcript trends while on imatinib
Wu, 2002^6^ | II | 400–600 | | 3/5 | Prognostic value of transcript trends while on imatinib
Merx, 2002^105^ | II | 400–800 | | 5/5 | Prognostic value of transcript trends while on imatinib
[underlined: Molecular predictors: Group 3–Interaction between the tyrosine kinase protein and imatinib]
Hochhaus, 2002^55^ | II | 400–600 | | 5/6 | Mutations in tyrosine kinase domain that may lead to imatinib resistance
Shah, 2002^108^ | Retro | Not stated | | 1/6 | Mutations in tyrosine kinase domain that may lead to imatinib resistance
[underlined: Molecular predictors: Group 4—Other factors]
Frater, 2003^109^ | II | 400 | | 1/5 | Bone marrow cellularity
Sneed, 2003^110^ | II | 300–400 | | 5/6 | Myelosuppression
Bhatia, 2003^27^ | | NS | | 2/5 | Persistent BCR-ABL in CD34+ after CCR with I
Paschka, 2003^10^ | II | 400–800 | | 4/6 | Evidence of BCR-ABL in CCR
O’Dwyer, 2003^35^ | II | Not stated | Matched controls | 2/5 | Abnormal cytogenetics in Ph cells

* Presented as peer-reviewed abstract only.

Abbreviations: Ara-C = cytarabine; I = imatinib; IFN = interferon; pts = patients; Ph = Philadelphia chromosome; Q-RTPCR = quantitative reverse transcriptase polymerase chain reaction; QOL = quality of life

Table 1d Details of included studies–Part 4 Studies included in the “Future Directions” only

First Author, Year | Trial Phase | Imatinib dose per day (mg) | Comparator | Quality | Comments
Additional articles included in Future Directions but not on other tables–Other factors
Mechanism of action
Kvasnicka, 2004^111^ | Retro | 400–600 | Patients treated with IFN or hydroxy-urea | 2/6 | I is associated with reversal of bone marrow angiogenesis–suggesting an anti-angiogenic capacity not seen with IFN
*Soverini, 2004[Soverini, 2004 #858] | II | 400 | | * | ABL mutations may be predictive of poor response
*Jabbour, 2004^112^ | Obs | Not stated | | * | Mutations in the p-loop and I binding pocket don’t correlate with outcome
*Branford, 2004^113^ | Unclear | Not stated | | * | Frequency of BCR-ABL mutations persists even with continued CCR > 24 mos
*Corm, 2004^114^ | II | 400–600 | | * | Mutations in the p-loop and I binding pocket lead to poorer prognosis
*Deininger, 2004 | Obs | Not stated | | * | Kinase domain mutations are correlated with phase of disease and clonal evolution
*Hochhaus, 2004^116^ | Obs | Not stated | | * | Kinase domain mutations are correlated with disease progression, especially p-loop
Approach to treatment
Shimoni, 2003^117^ | II | 400–600 | | 3/5 | Use of I to induce remission in Ph+ leukemias prior to allogeneic SCT
*Lange, 2004^118^ | II | | Molecular response durability between allogeneic SCT and I | * | Responses after allogeneic SCT may be more durable
*Palandri, 2004^119^ | Retro | 400–600 | | * | Evidence of response with I in the setting of relapsed CML after allogeneic SCT
*Pautas, 2004^120^ | Unclear | Not stated | | * | Evidence of response with I in the setting of relapsed CML after allogeneic SCT
*Conneally, 2004^121^ | Unclear | 300–600 | | * | Evidence of response with I in the setting of relapsed CML after allogeneic SCT
*Laurence, 2004^122^ | Obs | Not stated | | * | BC can still occur even with CCR on I
*George, 2004^123^ | Retro | Not stated | | * | May be differential response to I by race and ethnicity
*Bassi, 2004^124^ | II | 400 | | * | I is well tolerated in patients ≥ 65 years
*Martino, 2004^125^ | Retro | 400–600 | | * | I well tolerated and efficacious in pts >70 years
Diagnostic tests
Soverini, 2004^126^ | Retro | 400 | | 3/5 | Denaturing-HPLC method to screen for ABL point mutations
*Issa, 2004^127^ | Obs | Not stated | | * | Peripheral blood FISH for Ph+ possible, although inferior to bone marrow samples and RT-PCR
*Thomazy, 2004^128^ | Obs | Not stated | | * | Plasma samples can be used for Q-RT-PCR monitoring
*Kagami, 2004^129^ | Obs | Not stated | | * | cDNA microarrays may be a useful strategy to predict response to I
*Vallespi, 2004^130^ | Obs | 400 | | * | Further confirmation that BCR-ABL transcript ratios decrease with response to I
*Paschka, 2004^131^ | Obs | Not stated | | * | Methods of quantitating molecular response
*Albitar, 2005^132^ | II | 800 | | *
Upcoming clinical trials
*Berger, 2004^133; *^Hehlmann, 2005^134^ | III | 400 (with IFN, AraC, or after IFN) | All 4 arms contain I | * | *Berger, 2004^133; *^Hehlmann, 2005^134^
*Monroy, 2004^135^ | III | 400 vs 400 mg + AraC | Both arms contain I | * | *Monroy, 2004^135^
*Fruehauf, 2004^136^ | I/II | 600 with mitoxantrone, etoposide, and AraC | | * | *Fruehauf, 2004^136^
*Cornelissen, 2004^137^ | I/II | 200–800 with Ara-C at 200–1000 mg/m2/24hs | | * | *Cornelissen, 2004^137^
*Rousselot, 2004^138^ | I/II | 600 mg AraC and daunorubicin | | * | *Rousselot, 2004^138^
*Ceglarek, 2004^139^ | II | 300–800 | | * | *Ceglarek, 2004^139^
*Cortes, 2005^140^ | II | 800 | | * | *Cortes, 2005^140^

Presented as peer-reviewed abstract only.

Abbreviations: AP = accelerated phase; Ara-C = cytarabine; BC = blast crisis; BP = blastic phase; CP = chronic phase; CCR = complete cytogenetic response; HPLC = high performance liquid chromatography; I = imatinib; IFN = interferon; Obs = observational study; pts = patients; Ph = Philadelphia chromosome; Q-RT-PCR = quantitative reverse transcriptase polymerase chain reaction; QOL = quality of life; Retro = retrospective; SCT = stem cell transplant

## Efficacy

Evidence of efficacy of imatinib in CML can be best considered in terms of the matrix presented in Figure 5. Discrete studies are available for the first three CP clinical settings with the imatinib resistant setting addressed in the Future Directions section. The AP and BP clinical settings are presented in studies of mixed populations, represented on the respective tables. In addition, Table 7 presents those studies of mixed phases and Table 8 includes studies of imatinib combined with other treatments. Table 9 presents efficacy in terms of quality of life.

Figure 5 The CML therapy matrix

### Chronic phase

The most convincing and highest quality data for imatinib in CML is derived from the large phase III trial of imatinib vs. interferon plus cytarabine published in 2003 by O’Brien et al., the International Randomized Study of Interferon versus STI571 (IRIS).59 Prior to imatinib, interferon plus cytarabine was considered the standard of care for newly diagnosed CP CML when stem cell transplantation was not possible. In the RCT by Guilhot et al., published in 1997, interferon plus cytarabine was superior to interferon alone, with 41 percent achieving Major CR for the combined intervention vs. 24 percent for interferon alone (p=0.001), and 15 percent vs. 9 percent Complete CR rates.42 The estimated 3-year overall survival (OS) was 86 percent. The superior intervention from the Guilhot study was then the comparator for the IRIS trial.

In the IRIS phase III trial of imatinib vs. interferon plus cytarabine, imatinib was clearly superior with an 85 percent Major CR rate compared to 22% for interferon plus cytarabine, and Complete CR rates of 74 percent vs. 9 percent. While the OS presented in the original report was not different, PFS at 18 months was significantly better with imatinib (92 percent vs. 74 percent, p<0.0001). In a followup abstract report, the 30-month OS for imatinib was 95 percent (93–97 percent); OS for interferon plus cytarabine was not presented.62 The efficacy of the interferon plus cytarabine arm was not as good in IRIS as in the original Guilhot study (Major CR rate in IRIS 22 percent, Guilhot et al 41 percent), however the 30-month OS rates with imatinib in IRIS (95 percent) are still substantially higher than the 36-month OS rates with interferon and cytarabine from the Guilhot et al RCT (86 percent).

In addition to clinical response rates, other important treatment-related insights that can be derived from this group of studies includes the molecular impact of imatinib, timing of maximal treatment effect, dosing parameters, and tolerability of stem cell transplantation after imatinib.

Imatinib is a targeted drug that interacts with the BCR-ABL tyrosine kinase protein and ultimately leads to apoptosis and destruction of CML cells. Reduction in CML cells should lead to fewer cells with the Ph and therefore fewer cells producing the BCR-ABL mRNA. Reduction in the number of CML cells with Ph is the “cytogenetic response” described previously. Reduction in the number of cells producing the mRNA transcripts is the “molecular response.” Evidence of molecular response has been linked to survival,6,11 In terms of imatinib efficacy, Hughes et al. demonstrated that among IRIS patients who achieved a Complete CR at 6 months, imatinib led to more molecular responses (42 percent vs. 13 percent, p=0.01). Branford and colleagues demonstrated that 71 percent of IRIS participants obtained a Major MR (defined by this group as ≥3 log reduction in BCR-ABL/ABL transcript numbers) by 3 years. The rate of Major MR continued to increase over the first 2 years, and after that did not appear to increase or decrease substantially.32

Karntarjian, Cortes, and colleagues provided further insight into the timing of the response to imatinib in one of their phase II trial reports.63 Complete CR rates for imatinib increased from 34 percent to 60 percent over the period from 3 to 9 months. Meanwhile, the Complete CR rates for a group of historical controls that received interferon alone did not increase substantially after 3 months and, similarly, little increase was noted for interferon plus cytarabine patients after 6 months. A steady increase in the number of Complete CRs over 12 months was noted within studies of imatinib in the CP interferon refractory setting.8,70,73 Taken together with the molecular response data from IRIS,32 these data suggest that maximal responses to imatinib take longer than was previously seen with interferon-based regimens and that efficacy analyses need to be clearly presented in the context of duration of exposure to imatinib.

Uncontrolled phase II studies support the conclusion of the IRIS trial and provide additional clinical insight into the appropriate starting dose. Most convincingly, Kantarjian, Talpaz and colleagues treated patients with 800 mg of imatinib, and achieved better Complete CR rates as compared to historical controls who had received 400 mg of imatinib (90 percent vs. 74 percent).12 In an ongoing phase II trial by Hughes et al., the 600 mg dose appears to be leading to higher Major CR and Complete CR rates, as compared to a historical control group from the IRIS trial that received 400 mg.65 Direct comparisons between doses are not currently available.

Finally, possibility of stem cell transplantation after progression on imatinib was evaluated in an abstract presentation by Guilhot et al.62 Seventy-five IRIS participants went on to stem cell transplantation. There were no differences in survival after transplant between participants who received imatinib (N=30) and those who received interferon with cytarabine (N=45).

Table 2 Summary of efficacy of imatinib for CML–Chronic Phase, Newly diagnosed

Study ID | Imatinib dose [median length of follow up] | No. of patients, age, sex, additional CML characteristics | N | Major CR | Complete CR | Partial CR | Minor CR | Minimal CR | CHR | Survival/ Other
Chronic phase–newly diagnosed
Phase III
O’Brien, Guilhot, et al, 2003^59^ | 400 mg (increased to 800mg for no CHR at 3 months or at least a Minor CR at 12 months) [19 mo] | 1106 pts I: 553 50 [18–70] 62% M IFN + Ara-C: 553 51 [18–70] 56% M | I = 553 IFN + Ara-C= 553 Crossover from IFN + AraC to I = 318 Crossover from I to IFN + AraC = 11 | 85.2% 22.1% 55.7% 0% | 73.8% 8.5% 39.6% 0% | 11.4% 13.6% 16.0% 0% | | | 95.3% 55.5% 82.4% 27.3% | Rate of MCR at 18 mos: I = 97% (CI 84–90%) IFN + AraC = 35% (29–40%) (p<0.001) Rate of CCR at 18 mos: I = 76% (CI 72–80%) IFN + AraC = 15% (10–19%) (p<0.001) PFS at 18 mos: I = 92% IFN+Ara-C= 74% (p<0.001) OS at 18 mos: I = 97% IFN+Ara-C= 96% (p=0.23)
Hughes 2003 substudy11 | [19 mo] only included pts with CCR | I: 333 51 [18–70] 41% M IFN + Ara-C: 37 50 [21–70] 43% M | I = 333 6 mo IFN+AraC=37 6 mo | | MMR (≥3 log reduction) 42% 13% (p=0.01)
Branford 2003 sub-study33 | [30 mo for first line therapy; 17 mo for crossovers] | 55 pts - subset of above | I = 26 IFN + Ara-C= 27 Second line I (crossovers) = 24 | | 79% 7.4% 75%
*Guilhot, 2004 sub-study62 Abstract only | [30 mo] | | I = 553 12 mo 30 mo | | MMR (≥3 log reduction) 40% 90% | | | | | Estimated PFS at 30 mo = 88% (85–91%) Estimated OS at 30 mo = 95% (93–97%) 75 went on to SCT–no difference in OS after SCT between I (n=30) or IFN+Ara-C (n=45)
*Branford, 2004 sub-study32 Abstract only | [42 mo] | 32 pts–subset of above | I = 32 12 mo(n=26) 18 mo(n=26) 24 mo(n=26) 30 mo(n=26) 36 mo(n=25) 42 mo(n=24) | Med BCR-ABL log reduction 3.0 3.2 3.4 3.6 3.9 4.2 | MMR (≥3 log reduction) 46% 64% 68% 68% 71% 71% | ≥4 log reduction) 4% 4% 7% 25% 32% 54% | transcript level doesn’t appear to increase much past 24 mo)
Phase I/II
Karntarjian, Cortes, et al., 2003^63^ | 400mg [9 mo] | 50 pts (early phase CP) 50 historical controls 48 [15–79]; 26% > 60yrs 52%M 35 I pts had received short courses of hydroxyurea (33) or IFN (2; 2 wks) Historical controls = early phase CML-CP treated w/ hydroxyurea or IFN based regimens at single institution–only IFN and IFN+Ara-C historical control shown here | I = 50 3 mo 6 mo 9 mo Historical controls: IFN = 274 3 mo 6 mo 9 mo IFN + Ara-C = 257 3 mo 6 mo 9 mo | 74% 80% 77% 2% 11% 14% 9% 23% 23% | 34% 52% 60% 4% 3% 5% 1% 7% 8%
Karntarjian, Talpaz, et al., 2004^12^ | 800 mg [15 mo] | 114 pts 50 historical controls 48 [17–84] 61%M Historical controls were 50 pts with similar characteristics treated with Imatinib 400 mg | I = 114 Historical control = 50 | 95% 92% | 90% 74% | 5% 18% | 1% 6% | | 98% 98% | At median f/u 15 mo (range, 3–27 mo), 112 pts (98%) on I at 800mg are alive in chronic phase Estimated transformation-free status at 24 mo from KM: I 800 mg = 100% vs. historical controls 90% (p=0.0004)
Kantarjian, O’Brien, 2003^98^ Includes patients from Karntarjian, Cortes, et al., 2003^63^ and Karntarjian, Talpaz, et al., 2004^12^ | 400–800 mg [19 mo] | I: 187 pts (pts derived from several studies) 26%>60yr Historical controls: 87 pts (pts derived from several studies) 26%>60yr Historical controls = received prior IFN therapy otherwise not well described | I =187 IFN Historical control = 650 | 92% 50% | 81% 32% | 11% 18% | 3% 26% | | 97% 82% | Estimated from KM: OS at 2yr for I = 98% and IFN Historical Controls = 88% (p=0.01)
*Cortes, Talpaz, OBrien, Giles, et al., 2004^64^ Abstract only | 400–800 mg [36 mo for 400 mg group; 19 mo for 800 mg group] | 400 mg = 49 pts 800 mg = 181 pts 48 [15–84] | I @ 400 mg = 49 I @ 800 mg = 181 | | 81% 96% p=0.0002 | | | | | MMR CMR 47% 8% 67% 24% (both p≤0.02)
*Hughes, 2004^65^ Abstract only | 600–800 mg [12 mo] | 103 pts enrolled, data on 80 pts presented in abstract 47 [21–75] Gender not stated | I @ 600 mg = 80 I @ 400 mg = 556 in IRIS | 94% 84% p=0.0004 | 89% 69% P<0.0001 | | | | | MMR (≥3 log) 40% 47% p N/A

Abbreviations: * = abstract; Ara-C = Cytarabine; CR = cytogenetic response; CCR = complete cytogenetic response; CHR = complete hematological response; CMR = complete molecular response; f/u = followup; I = Imatinib; IFN = Interferon; K-M = Kaplan-Meier; OS = overall survival; M = Male; MMR = major molecular response; N = Number; NR = not reported; OS = Overall Survival; PFS = progression-free survival; pt(s)=patient(s); SCT = Stem cell transplant

### Chronic Phase - Interferon resistant or refractory

CML that has been previously treated is expected to be more resistant to the next therapy. Leukemic cells develop genetic or other changes that protect the cell and help them evade subsequent treatments. Hence, imatinib treatment of CML in the interferon resistant or refractory setting should be less efficacious than the newly diagnosed setting. As with most new treatments, imatinib was first tested in the clinical setting of patients who were resistant or refractory to interferon-based therapies, the gold standard treatment at the time (when stem cell transplantation was not possible). This group of studies provides information on imatinib efficacy in the treatment resistant and refractory setting, timing of best imatinib response, duration of response (PFS), survival (OS) and dose response.

Several phase II studies of imatinib for interferon resistant or refractory disease exist (Table 3). In the first major published imatinib clinical trial, Druker and colleagues demonstrated that imatinib had activity in the interferon resistant or refractory setting, documenting Major CRs of up to 50 percent.66 This was a landmark study, establishing that an oral targeted therapy could have dramatic activity in a disease resistant setting.

Kantarjian, Sawyers and colleagues conducted the largest phase II open-label study.2 Efficacy estimates from this study of 400 mg daily with a median duration of imatinib treatment of 17.9 months indicated that the Major CR rate for the interferon resistant or refractory group of patients was 60 percent with a Complete CR rate of 41 percent. The imatinib dose was increased to 800 mg when patients had not achieved a CHR by 3 months, a Major CR by 12 months, or relapsed after CHR. These estimates have been pretty consistent across this entire group of studies.8 Patients treated earlier in their course (early CP, i.e., <1 year since diagnosis) have fared better than those whose disease is in late CP (>1 year since diagnosis), with a 62 percent Complete CR rate for early CP and 41 percent for late.44 The estimates were slightly higher than reported for interferon resistant or refractory CP in the 2002 FDA approval summary (Major CR 31 percent, Complete CR rate 13 percent).82

Reasons for needing to change from interferon-based therapy varied, and included resistance to the medication (failure to achieve the desired response within a defined timeframe), relapse (return of disease after response has been achieved), and intolerance (non-hematologic ≥ Grade 3 toxicity). Patients with hematologic or cytogenetic relapse after interferon-based therapy had higher response rates to imatinib than those with resistant disease after 6 months of therapy (cytogenetic relapse after interferon, 76 percent Complete CR with imatinib; cytogenetic resistance to interferon, 31 percent Complete CR with imatinib). Patients who were interferon intolerant had intermediate response rates, however this group was older than the other patient participants (50 percent with age ≥60 vs. 40 percent for rest of participants), consistent with the fact that they were not tolerating the side effects of interferon well.

As observed with the newly diagnosed group, cytogenetic responses continued to accrue after up to 12 months of imatinib therapy.8, 73 Periods after 12 months were not reported. Importantly, though, patients who achieved any CR early (i.e., by 3 months) had substantially longer PFS and OS (OS if achieved Major or Minor CR by 3 months, 95 percent, if not 72 percent, p<0.0001).72 Similarly, an early Major CR that is achieved by 6 months was also associated with longer PFS and OS (OS if achieved Major CR by 6 months, 95 percent, if not 78 percent, p=0.001). Extending these findings to molecular responses, Rosti et al. report that overall survival is better is a major molecular response is achieved.8

Because the interferon resistant or refractory is the oldest group of longitudinal studies of imatinib in CML, the longest survival followup data are available for this group of patients. Duration of response and survival are reflected in the 4-year follow up study by Kantarjian, Cortes, and colleagues.72 Among their full cohort of 261 patients they described a 4-year OS rate of 86 percent and PFS of 80 percent. They compared these PFS rates to a matched cohort of historical controls under treatment at their institution from 1982 to 1997. The historical cohort had a 4-year PFS of 43 percent (compared to the imatinib cohort p<0.0001).

Appropriate dosing continues to be a question. Phase I dose ranging studies with phase II outcomes correlates demonstrated that doses in the 500 mg range were most efficacious.66 Some patients resistant to lower doses of imatinib achieved a response when the dose was increased to 800 mg.71, 74 As expected, response rates were lower (Complete CR 5–19 percent) and less durable (43 percent with loss of response by 416 days). Similarly, increasing the dose could overcome relapses, such that patients who relapsed at 400 mg imatinib could still achieve a cytogenetic response when the dose was increased to 800 mg (18 percent Complete CR).71 Finally, Cortes et al. reported 89 percent Complete CR rates when the initial imatinib dose was 800 mg, although only 33 participants were involved in this study.69

One challenge for this group of studies is that there are several publications presenting data from different combination of the same group of patients.2, 70–72 These patients were recruited through several phase II industry-sponsored trials (Novartis 110, 112, 113) and the various publications represent different clinical questions, analyses, comparison groups, and followup periods. There is a risk of misinterpreting these as multiple independent datasets corroborating the efficacy estimate.

Table 3 Summary of efficacy of imatinib for CML –Chronic phase, interferon resistant or refractory

Study ID | Imatinib dose [median length of follow up] | No. of patients, age, sex, additional CML characteristics | N | Major CR | Complete CR | Partial CR | Minor CR | Minimal CR | CHR | Survival/ Other
Chronic phase–interferon resistant or refractory
Phase I/II
Druker, Talpaz, et al., 2001^66^ | 25–1000 mg/d [8.5 mo (1 wk to 8.5 yr)] | 83 pts 55 [19–76] 66% M | I = 83 I Dose: < 50 mg= 6 85 = 4 140 =3 200–250=16 300–1000=54 Higher dose ranging: 330–350mg 400 500 600 750 800 1000 Total N = 54 | 38% 50% 17% 50% 33% 12% 14% 31% | | | 15% 33% 17% 50% 0% 25% 1% 22% | | 77% 0% 25% 33% 56% 99% | Median time to best cytogenetic response = 147 days
Braziel, 2002 substudy67 | 300–600 mg [mean 3.5 yr; range 1.1–9.1 yr.] | 19 pts 57[19–70] 47% M | I = 19 | 64% | 32% | 32% | | | 95% | All pts with CCR were still cytogenetically negative at 14 mo; 5/6 also with CMR
Kantarjian, Sawyers, et al., 2002^2^ | 400 mg (increased to 800 mg for no CHR at 3 months, no MCR at 12 months, or relapse after CHR) [med duration of treatment with I = 17.9 mo (0.5–20.3)] | 532 pts 57 yrs. [18–81] 60% M 454 of these were confirmed chonic phase patients | I = 454 IFN/hematologic failure: Resistance = 63 Relapse = 70 IFN/cytogenetic failure: Resistance = 119 Relapse= 41 IFN intolerant = 161 | 60% 41% 57% 55% 83% 66% | 41% 25% 41% 31% 76% 47% | 19% 16% 16% 24% 7% 19% | 5% 8% 1% 8% 2% 2% | 11% 16% 16% 9% 2% 11% | 95% 89% 99% 97% 98% 93% | Median 18 mo PFS = 89% (95% CI, 86 to 92%) Median 18 mo OS = 95% Median time to cytogenetic relapse 12 mo (range 6–19) and 6 mo (range 3–14) from time of MCR If dose increase necessary, CHR in 9% and CR in 11%
Marin, Marktel, Szydlo, et al., 2003 sub-study68 | | Subset of 143 pts >60yr = 24% 54%M Historical controls = 246 CML CP pts from the Medical Research Council CML 3 trial of IFN vs busulfan or hydroxyurea who didn’t respond to IFN | I = 143 Historical control = 246 | 55% | 34% | 19% | 4% | | | Treatment with I: RR for mortality 0.54 (CI 0.31–0.93, p=0.026) RR for PFS 0.40 (CI 0.20–0.77, p=0.0065)
Cortes, Giles, et al, 2003^69^ | 800 mg [15 mo] | 33 pts 47 [30–75] 22% >60 yr 42% M | I = 33 | 90% 97% durable | 89% | | | | | All alive at 16 mo median f/u, except two that stopped therapy (1 = arthritis; 1= noncompliant)
Karntarjian, Talpaz, et al., 2002^70^ Includes some patients presented in Kantarjian, Sawyers, et al., 2002^2^ | 400 mg (increased to 800mg for no CHR at 3 months, no MCR at 12 months, or relapse after CHR) [17 mo (1–21)] | 249 pts 34% >60 yrs 57%M | I = 249 3 mo 6 mo 12 mo | 62% 44% 47% 57% | 45% 25% 28% 38% | | | | | 18 mo PFS = 93% 18 mo OS = 96% Any cytogenetic response at 3 months: Yes–PFS at 18 mo = 100% No–PFS at 18 mo = 85% (p<0.001) Yes–OS at 18 mo = 100% No–OS at 18 mo = 95% (p<0.001)
Karntarjian, Talpaz, et al., 2003^71^ Includes patients from Kantarjian, Sawyers, et al., 2002^2^ and Karntarjian, Talpaz, et al., 2002^70^ | 400–800 mg Planned dose escalation from 400 mg to 800 mg, or to 600 mg daily if the dose had been reduced to 300 mg daily if no CHR at 3 mo, no MCR at 12 mo, heme relapse, or cytogenetic relapse, defined as an increase of Ph+ cells by at least 30% [Median duration of I = 13mo] | 54pts 58 [24–77] 43% >60 yrs 57%M | I = 54 High dose I for no response to 400mg N=20 High dose I for cytogenetic relapse N=34 | 43% 5% 38% | 18% | 20% | | | 65%
Kantarjian, O’Brien, 2004^44^ Includes patients from Kantarjian, Sawyers, et al.,.2002^2^, Karntarjian,Talpaz, et al., 2002^70^ and Karntarjian, Talpaz, et al., 2003^71^ | 400 mg (increased to 800 mg for no CHR at 3 months, no MCR at 12 months, or relapse after CHR) [34 mo for I; 109 mo for historical control] | Early CP: I = 261 pts 34% > age 60; Historical control = 204 pts 19% > age 60 Late CP: I = 147 pts 39% > age 60; Historical control = 95 pts 9% > age 60 Historical controls = CML-CP treated w/ IFN based regimens from 1982–1997 whose disease progressed and were treated with some other subsequent therapy | Early CP I = 261 Historical control = 204 Late CP I = 147 Historical control = 95 | 73% 24% 59% 11% | 62% 19 % (p<0.001) 41% 7 % (p<0.001) | 11% 5% 18% 4% | 10% 13% | | 97% 53% 95% 58% | Estimated 2 yr OS from KM I (early CP)= 95% Historical control = 70%
Karntarjian, Cortes, et al., 2004^72^ Includes patients from Kantarjian, Sawyers, et al., 2002^2^, Karntarjian, Talpaz, et al., 2002^70^ and Karntarjian, Talpaz, et al., 2003^71^ | 400 mg (increased to 800 mg for no CHR at 3 months, no MCR at 12 months, or relapse after CHR) [45 mo for I; 109 mo for historical control] | I = 261 pts 34% > age 60 Historical control = 251 pts 17% > age 60 Historical controls = CML-CP treated w/ IFN based regimens from 1982–1997 whose disease progressed and were treated with some other subsequent therapy | I=261 Historical control = 251 | 73% | 63% | 10% | 5% | Major MR 43% | Complete MR 26% | Estimated K-M: For imatinib: 4-yr OS = 86% 4-yr PFS = 80% Major or Minor CR at 3 mo: Yes - 4-yr PFS = 93% 4-yr OS = 95% No - 4-yr PFS = 55% 4-yr OS = 72% (p for both analyses ≤0.001) Major CR at 6 mo: Yes - 4-yr PFS = 93% 4-yr OS = 95% No - 4-yr PFS = 65% 4-yr OS = 78% (p for both analyses ≤0.001) For historical control: 4-yr PFS = 43%
Le Coutre, 2003^73^ | 400 mg [9mo] | 39 pts 56 [23–80] | I = 39 3 mo (N=33) 6 mo (N=27) 9 mo (N=13) 12 mo (N=3) | 21% 33% 62% 67% | 6% 30% 62% 33% | 15% 3% 0% 33%
Marin, Goldman, et al., 2003^74^ | 600–1000 mg [416 days (212–790)] | 36 pts (27 IFN refractory and 9 newly diagnosed)–all treated with higher dose I for failure to achieve CCR on I 400mg age/gender not stated | I = 36 | 39% | 19% | 20% | | | | Cytogenetic response short-lasting– 43% with loss of response at med f/u (timeframe not clearly stated)
Marin, Marktel, Bua, et al., 2003^75^ | 200–800 mg [not stated] | 145 pts 53 [17–76] (>65 yr = 17%) 47%M All IFN refractory; 14% received autoSCT | I = 145 | 29% | 19% | | | | | 12 mo OS = 87% (CI 92–80%) 24 mo OS = 63% (CI 78–56%) 12 mo PFS = 75% (CI 68–83%) 24 mo PFS =52% (CI 47–60%)
Rosti, 2004^8^ | 400mg [26 mo] | 191 pts age/gender not stated | I = 191 3 mo 6 mo 9 mo 12 mo | 61% 41% 44% 42% 48% | 44% 16% 27% 29% 33% | | | | 89% 89% 89% 86% 80% | At med f/u 26 mo, OS estimated from KM: MCR achieved 97% MCR not achieved 92% (p=0.037)

Abbreviations: * abstract; CI = 95% confidence interval; CML = Chronic myelogenous leukemia; CP = chronic phase; CR = cytogenetic response; CCR = complete cytogenetic response; CHR = complete hematological response; CMR = complete molecular response; f/u = follow-up; I = Imatinib; IFN = Interferon; K-M = Kaplan-Meier; M = Male; MCR = major cytogenetic response; N = Number; OS = Overall Survival; PFS = progression-free survival; pt(s)=patient(s); RR = relative risk; SCT = Stem cell transplant

### Chronic phase - Previous stem cell transplant and heavily pretreated

As the number and intensity of previous treatment increases, there is progressive decrease in the chance of response to new treatments. A critical question for imatinib is whether it is an option for patients who have become resistant to multiple prior therapies, and whether it precludes other subsequent therapy. Of particular interest is stem cell transplantation (SCT, a.k.a. bone marrow transplantation), which includes intensive myelosuppressive cytotoxic chemotherapy often with multiple agents. Allogeneic transplant also carries a substantial risk of graft versus host disease (GVHD).

Cervantes et al. demonstrated that 400 mg of imatinib yielded substantial Complete CR rates for 33 patients with prior autologous SCT (33 percent at 12 months), similar to that of the comparison sample of 65 interferon refractory patients who had not had a transplant (38 percent; Table 4).37 Similar response rates were substantiated across this group of trials, with some studies noting even substantially higher Complete CR rates (33–85 percent).

Table 4 Summary of efficacy of imatinib for CML – Chronic phase, Previous stem cell transplant/heavily pretreated

Study ID | Imatinib dose [median length of follow up] | No. of patients, age, sex, additional CML characteristics | N | Major CR | Complete CR | Partial CR | Minor CR | Minimal CR | CHR | Survival/ Other
Chronic phase –previous stem cell transplant/heavily pretreated
Phase I/II
Cervantes, 2003^37^ | 400 mg [f/u not stated; at least 12 mo.] | Prior autoSCT: 33 pt 53 yr [24–70] 61% M No autoSCT/IFN refractory: 65 pt 53 yr [17–80] 54% M Both groups received I | Prior autoSCT: I = 33 3 mo 6 mo 12 mo No autoSCT IFN refractory: I = 65 3 mo 6 mo 12 mo | 42% 45% 55% 47% 52% 66% | 21% 24% 33% 20% 35% 38% | 21% 21% 22% 27% 17% 28% | 14% 10% 11% 20% 19% 8% | | | PFS = 93.7% PFS= 96.7% (p NS)
Fischer, 2002^77^ | 400 mg [28 wk] | 24 pt–disease relapse after autologous transplant 56 yr. [25–64] 58% M (only 15 CML-CP pt reported here; f/u period for AP and BP not long enough for endpoints) | I for CP relapse after autoSCT = 15 | 61% | 46% | 15% | 8% | 8% | 100%
Kantarjian, O’Brien, et al., 2002^78^ | 400–1000 mg [16 mo] | 28 pt 43 yr [25–64] 57% M (All with prior allogeneic SCT; 1 CP in CHR, 4 CP active, 3 AP in CHR, 12 AP active, 8 BP; 23 evaluable) | I = 28 (23 evaluable) | 58% | 35% | 23% | | | 74% | OS 1-yr 74% for all, and 100% treated in CP
O’Brien, Giles, et al., 2003^79^ | Not stated [46 mo] | 90 pt 46 [25–64] (age >60yr 4%) 51% M | I = 90 (given after relapse from IFN, Ara C, and homoharring tonine allogeneic SCT) | 78% | 65% | 13% | 5% | | | Estimated 5-yr OS = 88%
Hess, 2004^80^ | 400 mg [381 day] | 37 pt | I = 37 (given for CP relapse after allogeneic SCT) | | 85% of 11/13 with cytogenetic relapse only | | | | | 25/27 (67%) achieved CMR 1 mild reactivation of GVHD OS at 1.7 yr = 100%
*Corsetti, 2004^81^ Abstract only | 400 mg for CP 600 mg for AP [36 mo] | 50 pt Age & gender not specified CML-CP & AP relapsed after autoSCT & IFN | I= | | CCR 61% | Major 70% | | | | At median f/u of 36 mo: PFS 78% OS 87%

Abbreviations: * abstract; AP = Accelerated phase; Ara-C = Cytarabine; BP = Blastic phase; CML = Chronic myelogenous leukemia; CP = chronic phase; CR = cytogenetic response; CCR = complete cytogenetic response; CHR = complete hematological response; CMR = complete molecular response; f/u = follow-up; GVHD = graft versus host disease; I = Imatinib; IFN = Interferon; M = Male; N = Number; OS = Overall Survival; PFS = progression-free survival; pt(s)=patient(s); SCT = Stem cell transplant

### Accelerated phase

CML that is more advanced at presentation has a poorer prognosis. Imatinib is still efficacious in the accelerated phase setting, as demonstrated by Talpaz et al. (Table 5).87 Complete CR rates ranged from 11 to 19 percent, with the 600 mg dose being more efficacious than 400 mg. In a subsequent follow up abstract, the Major CR rate was 48 percent with a median follow up of 38 months and the median survival had not been reached. A group of historical controls (accelerated phase, not otherwise described) were reported to have a median survival of 21 months.88 The 3-year OS was estimated at 53 percent.

Table 5 Summary of efficacy of imatinib for CML–Accelerated phase

Study ID | Imatinib dose [median length of follow up] | No. of patients, age, sex, additional CML characteristics | N | Major CR | Com- plete CR | Partial CR | Minor CR | Minimal CR | CHR | Survival/ Other
Accelerated Phase: Phase I/II
Talpaz, 2002^87^ Follow up data in abstract: *Cortes, Talpaz, OBrien, Gracia-Manero, et al., 2004^88^ | 400–800 mg [median treatment duration 10–11 months; median f/u not stated] (initially at 400 mg daily, later increased to 600 mg, and subsequently 800 mg allowed for inadequate response) [38 mos] | 235 pts (235 pts enrolled but only 181 pts with confirmed diagnosis presented) 58 [22–86] 50%M 34% previously untreated 66% previously treated | I = 181 I @ 400mg = 62 I @ 600mg = 119 I = 171 | 24% 16% 28% 48% | 17% 11% 19% | 7% 5% 8% | 7% 8% 6% | 17% 15% 18% | | TTP estimated K-M > 1-yr: All doses = 59% (CI 52–66%) 400mg I = 44% (CI 31–56%) 600mg I = 67% (CI 59–76%) (p=0.002) 1 yr OS estimated K-M: All doses = 74% (CI 68–81%) 400mg I = 65% (CI 53–77%) 600mg I = 78% (CI 70–87%) Median survival not reached at med of 38 mo f/u (21 mo for historical controls)– estimated at 53% at 3 yr

Abbreviations: * = abstract; AP = Accelerated phase; CHR = complete hematologic response; CI = 95% confidence interval; CML = Chronic myelogenous leukemia; CP = chronic phase; CR = cytogenetic response; I = Imatinib; K-M = Kaplan-Meier; M = Male; N = Number; OS = Overall Survival; PFS = progression-free survival; pt(s)=patient(s); TTP = time to progression

### Blastic phase/blast crisis

During the chronic phase there is massive clonal expansion of CML cells. In the blastic phase the cells lose the ability to differentiate and the leukemia advances rapidly. Blastic phase CML has the poorest prognosis with an expected survival of 3–6 months. Historically it has been poorly responsive to any therapy. Median survival is 21–29 weeks, even with aggressive acute leukemia treatment plans.141 Database review studies have indicated a 10-year survival after bone marrow transplantation of 0 percent (1996 report).142

Imatinib has been shown to have efficacy in the blastic setting (Table 6). Sawyers et al. report the largest Phase II trial involving 260 participants with a median duration of treatment of 4 months.3 A total of 31 percent had a sustained CHR for over 4 weeks and 7 percent had a Complete CR. For those who did respond to imatinib, the estimated median response duration was 10 months. OS was estimated as 6.9 months (95 percent CI, 5.7–8.7 months) with 43 percent survival at 9 months and 20 percent at 18 months. In all studies that evaluated response by blast type, lymphoid blast crisis had better response rates than non-lymphoid (myeloid) blast crisis.89, 90 Previously untreated patients always had a better response than those who were previously treated.3 Doses ranged from 400–1000 mg without a clear pattern for maximal efficacy. Sawyers et al. started with 400 mg and increased to a maximum of 800 mg when the disease was resistant or refractory.3

Table 6 Summary of efficacy of imatinib for CML –Blastic phase/blast crisis

Study ID | Imatinib dose [median length of follow up] | No. of patients, age, sex, additional CML characteristics | N | Major CR | Com- plete CR | Partial CR | Minor CR | Minimal CR | CHR | Survival/ Other
Blastic Phase/Blast Crisis
Phase I/II
Druker, Sawyers, et al., 2001^89^ | 300–1000 mg dose escalation [74 days (1–349 days)] | 58 pts 48 yr [24–76] 60% M BC or Ph+ ALL resistant or refractory to standard induction | I in Myeloid BC=38 I in Lymphoid BC and Ph+ALL= 20 | | | | | | 11% 20% | TTP = 84 days [42–194] TTP = 58 days [42–123]
Kantarjian, Cortes, 2002^90^ | 300–1000 mg [11 mos] | 75 pts 53 yr [27% >60 yr] 67% previously untreated 33% previously treated | I = 75 I in Nonlymphoid BC = 65 I in Lymphoid BC = 10 | | 6% 5% 10% | 3% 3% | 3% 3% | | 21% 23% | Median OS = non-lymphoid BC =6.5 mo 28% 1 yr survival for non-lymphoid BC Lymphoid BC =7.0 mos. Compared to historical controls that received standard Ara-C based induction chemotherapy, I = 55% objective response rate vs 29% with Ara-C (p=0.001); 4- week mortality = 4% with I and 15% with Ara-C (p=0.07); median survival was 7 mo with I and 4 mo with Ara-C (p=0.04)
Sawyers, 2002^3^ | 400 mg (later in study dose escalation for treatment resistance was allowed to max 800 mg) [median duration of treatment 4 mos, f/u not stated] | 260 pts 56 [19–81] 52% 57% previously untreated 43% previously treated | I = 260 Previously untreated = 148 Previously treated = 81 | 16% 16% 17% | 7% 8% 6% | 9% 7% 11% | 2% 2% 1% | 13% 15% 10% | 52% Sustained >4wks = 31% Sustained = 36% Sustained = 21% | Estimated PFS at 6 mos = 68% (CI 57–79%) Estimated median response duration = 10ms (CI 7.2–12.6) OS estimated from KM = median 6.9 mos (CI, 5.7–8.7) with 43% survival at 9 mos and 20% at 18 mos
Sureda, 2003^4^ | 600 mg [f/u not stated] | 30 pts 50 [18–72] 53%M All pretreated, 70% with multiple previous regimens | I = 30 | 3% | 0% | 3% | 10% | | 30% | Median response duration of CHR = 5 mos (range 4–18) EFS at 1 yr = 29% (SD 8%) OS at 1 yr = 36% (SD 13%)

Abbreviations:

* = abstract; ALL = Acute Lymphocytic Leukemia; Ara-C = Cytarabine; BC = Blastic crisis; BP = Blast phase; CI = 95% confidence interval; CML = Chronic myelogenous leukemia; CR = cytogenetic response; CHR = complete hematological response; EFS = event-free survival; f/u = followup; M = Male; N = Number; OS = Overall Survival; PFS = progression-free survival; Ph+ = Philadelphia chromosome positive; pt(s)=patient(s); TTP = time to progression

### Additional efficacy tables

Table 7 reviews three reports that presented response to imatinib across phases. Two reports were summed from the three large phase II Novartis trials submitted to the FDA as part of the 2002 imatinib approval process.82, 83 These studies are instructive in that they provide validation of the differential effect of imatinib therapy by phase of disease and the efficacy estimates previously presented, as well as additional estimates of treatment durability. With a median follow up of 40 months 64 percent of CP participants were still taking imatinib.83 Among CP patients with Major CR, 82 percent were still on imatinib at 3 years, with PFS 80 percent and OS 88 percent. For AP and BP the 3-year PFS was 55 percent and 5 percent, respectively. A third study conducted with 128 patients who had a prior allogeneic SCT also validates the differential effect of imatinib by phase and the activity of imatinib in the heavily pretreated post-allogeneic SCT setting.84 The overall and CP Complete CR rates of 42 percent and 58 percent described were consistent with the previous group of allogeneic studies.

Table 8 presents two additional studies that did not naturally fit into the other tables. Both of these were preliminary trials assessing the tolerability and efficacy of drug combinations including imatinib in newly diagnosed CP CML. Gardembas and colleagues described imatinib combined with cytarabine38 and Baccarani et al. reported imatinib plus pegylated interferon.91 Both trials reported Complete CR rates that were no better than those seen in the IRIS study with imatinib alone. Interpretation of these trials is limited by the shorter follow up periods; additional cytogenetic and molecular responses may accumulate with time making these combination therapies more interesting as the data mature.

Table 7 Summary of efficacy of imatinib for CML–Mixed phases

Study ID | Imatinib dose [median length of follow up] | No. of patients, age, sex, additional CML characteristics | N | Major CR | Complete CR | Partial CR | Minor CR | Minimal CR | CHR | Survival/ Other
Mixed Phases
Phase I/II
Cohen, 2002^82^ This is the FDA Approval Summary–most of these patients are presented elsewhere predominantly as the 3 large phase II Novartis trials–see individual tables | Phase I = 25–1000 mg Phase II = 400–600 mg | IFN refractory CP: 83 pts CP: 532 pts 57 yr. [18–90] 59% M AP: 235 pts 56 yr [22–86] 50% M BC: 260 pts 56 yr [19–81] 52% M | I in IFN refractory CP = 83 I in CP = 532 I in AP = 235 I in BC = 260 | 31% 49% 21% 13.5% | 13% 30% 14% 5% | | | | 98% [when dose > 300 mg] 88% 63% 26% | Median time to hematologic progression for CML-AP = >6 mo Median time to hematologic progression for CML-BC = 5.6 mo
Silver, 2004^83^ Follow up data presented in abstract form only | CP–400 mg AP / BP–400–600 mg Dose escalation to 800 mg allowed in later parts of the studies 40 mos for CP participants] | CP–532 pts (all late CP) AP–235 pts BP–260 pts Unclear how many are IFN refractory | I - CP = 532 I - AP = 235 I - BP = 260 | 65% | 52% | 13% | | | | CP: 64% still on I 82% of those with MCR continue @ 3 yr 3 yr OS = 88% 3 yr PFS = 80% AP: 25% still on I When at 600mg dose, 55% 3yr PFS BP: 5% still on I When at 600mg dose, 14% 3yr PFS
Olavarria, 2003^84^ | 400–600 mg [9 mos] | 128 pts 45 yr [17–65] 62% M All with previous allogeneic SCT; 40% received donor lymphocyte infusion; heavily pretreated | I = 123 I in CP after alloSCT = 50 I in AP after alloSCT = 29 I in BP after alloSCT = 44 | 54% 71% 67% 44% | 42% 58% 48% 22% | 12% 13% 19% 22% | | | 71% 98% 83% 32% | Estimated 2-yr OS: All = 65% AP = 86% BP = 12% (p for AP vs BP <0.0001)
Lahaye, 2005^85^ | 400–600 mg. CP [33 mo, 6–49] AP [28 mo, 0.4–50] BC [6 mo, 0.1–52] | 300 pts 56.2 yr [14.6–79.6] 57% M CP = 139 pts 55.9 yr [18.5–76.6] 56% M AP = 80 pts 60.9 yr [30.9–81.8] 66% M BC = 76 pts | 300 pts CP: I = 139 [median duration = 34 mo (19–49) AP: I= 80 [median duration = 28 mo(0.4-50) BC: I = 76 | | 49% 26% 8% | 12% 5% 4% | 4% 9% 3% | 27% 36% 34% | 97% 61% 18% | @30 mo, estimated DFS = 83%; CHR @ 30 mo = 79% MCR after 3 mo =longer DFS (p=0.009) MCR after 6 mo = longer DFS (p=0.004) MCR after 12 mo= longer DFS (p=.0001) & improved OS (p=0.021) AP: DFS & OS were not predictive BC: Estimated survival @ 12 mo =32% @ 24 mo = 18% OS = 6 mo (0.9-52)
Deshmukh, 2004^86^ Abstract only | “Recommended doses” [Not stated] | 174 pts Participant profile not described CP = 97 pts (of which 24 = early CP) AP = 47 pts BP = 30 pts | CP, I = 97 CP (early CP subset), I=24 AP, I = 47 BP, I = 30 | 50% 63% 21% 23% | 31% 21% 6% 13% | | | | 92% 100% 55% 37%

Abbreviations: * = abstract; AP = Accelerated phase; BC = Blast crisis; BP = Blastic phase; CI = 95% confidence interval; CML = Chronic myelogenous leukemia; CP = chronic phase; CR = cytogenetic response; CHR = complete hematological response; DFS = Disease free survival; I = Imatinib; IFN = Interferon; M = Male; MCR = major cytogenetic response; N = Number; OS = Overall Survival; PFS = progression-free survival; pt(s)=patient(s); QOL = Quality of life; RR = relative risk; SCT = Stem cell transplant

Table 8 Summary of efficacy of imatinib for CML–Other types of studies

Study ID | Imatinib dose [median length of follow up] | No. of patients, age, sex, additional CML characteristics | N | Major CR | Complete CR | Partial CR | Minor CR | Minimal CR | CHR | Survival/ Other
Imatinib efficacy/other
Phase I/II
Gardembas, 2003^38^ | 400 mg (with Ara-C SQ 20 mg/m^2^/d on d15-28) [12 mo] median 6 cycles of Ara-C | 30 pts 48 yrs [22-81] 67% M Newly diagnosed CML-CP | I+AraC= 30 3 mo 6 mo 9 mo 12 mo | 70% 73% 77% 83% | 23% 57% 53% 70% | 47% 17% 23% 13% | 6% 10% 6% 6% | | 100% 100% 100% 97% | No CCR @ 3 mos = 6% No CCR @ 6 mos. = 6% No CCR @ 9 mos. = 3% No CCR @ 12 mos. = 3 %
Baccarani, 2004^91^ | 400 mg (with pegylated IFN at 50 mcg/d, 100 mcg/d, or 150 mcg/d) [min 6 mo] | 76 pts 47 yrs [18-68] 58%M Newly diagnosed CML-CP | I+PegIFN=76 | 83% | 70% | 13% | | | 97% | CCR similar in all IFN cohorts 47% with BCR-ABL transcript reduction by >3 log

Abbreviations: * = abstract; CML = Chronic myelogenous leukemia; CP = chronic phase; CR = cytogenetic response; CHR = complete hematological response; I = Imatinib; IFN = Interferon; M = Male; N = Number; OS = Overall Survival; pt(s)=patient(s)

### Quality of Life

Quality of life (QOL) is another important efficacy outcome. Hahn and colleagues investigated the QOL of newly diagnosed CP patients receiving imatinib vs. interferon plus cytarabine in the IRIS study.60, 61 The Functional Assessment of Cancer Therapies–Biologic Response Modifiers (FACT-BRM) instrument was used.143 The primary QOL outcome was the Trial Outcome Index (TOI; 27 items, score range 0-–108) and secondary endpoints included social/family well-being (SFWB; 7 items range 0–28) and emotional well being (EWB; 6 items, range from 0–24). Higher scores indicated better QOL. Quality of life was measured at baseline, monthly for 6 months, then at 9, 12, and 18 months. Imatinib treated patients scored significantly higher on all of these QOL measurements. The mean TOI across the trial was 84.4 for imatinib treated patients and 67.7 for patients on interferon plus cytarabine (p<0.001). Patients on the interferon plus cytarabine arm had a substantially greater decrease in TOI across time than those on imatinib. This work was recently repeated in a phase II study conducted by Pasquini and colleagues in Brazil.76 Imatinib led to clinically significant increases in TOI at 1, 6 ,and 12 months.

Table 9 Summary of efficacy of imatinib for CML–Quality of Life

Study ID | QOL scales used/measurements obtained | Imatinib dose [length of follow up] | No. of patients, age, sex, additional CML characteristics | QOL outcomes
Hahn, 2003^60, 61^ | FACT-BRM Within the FACT-BRM, the primary outcome was the TOI; (27 items, score range 0-108) Secondary endpoints included SFWB (7 items range 0-28) and EWB (six items, range from 0-24). Higher scores are better. baseline monthly for 6mo and then at 9, 12, and 18 mo | 400 mg (increased to 800mg for no CHR at 3 months or at least a Minor CR at 12 months) [19 mo] [30 mo for first line therapy; 17 mo for crossovers] | CP newly diagnosed 1049 pts Imatinib: 530 50 [18-70] 62% M IFN+AraC: 519 51 [18-70] 56% M | TOI (mean across trial) Imatinib 84.4 IFN+AraC 67.7 (p<.001) SFWB (mean across trial) Imatinib 22.8 IFN+AraC 21.6 (p<.001) EWB (mean at 18 mo timepoint) Imatinib 19.5 IFN+AraC 17.7 (p<.001) Based upon 1,3,6,9, and 12 mo data: % of participants with clinically meaningful [underlined: decrease] in TOI by 5 or more points (goal = increased TOI) Imatinib 22-29% across timepoints IFN+AraC 52-73% across timepoints p<0.001 % of participants with clinically meaningful increase in TOI by 5 or more points Imatinib 29-43% across timepoints IFN+AraC 9-25% across timepoints p not stated
*Pasquini, 2004^76^ Abstract only | FACT-BRM Primary outcome = TOI Baseline monthly for 6mos and then at mos 9,12,and 18 | 00-600 mg | CP - IFN refractory 230 pts All received imatinib 46 [18-76] 56%M | % of participants with clinically meaningful increase in TOI by 5 or more points All received I: 1 mo–increase by 5.4 (p<0.0001) 6 mo–increase by 7.4 (p<0.0001) 12 mo–increase by 9.8 (p<0.0051)

Abbreviations: * = abstract; AraC = Cytarabine; CML = chronic myelogenous leukemia; CP = chronic phase; emotional well being (EWB); FACT-BRM = Functional Assessment of Cancer Therapies - Biologic Response Modifiers; I = Imatinib; IFN = Interferon; M = Male; N = Number; pt(s) = patient(s); QOL = Quality of life; social/family well-being (SFWB); Trial Outcome Index (TOI)

## Adverse events

Table 10 reviews the adverse events reported across the studies. In the IRIS trial, imatinib most commonly caused neutropenia (61 percent), thrombocytopenia (57 percent), superficial edema (56 percent), nausea (44 percent), and abnormal liver function results (43 percent).59 Interferon plus cytarabine most commonly caused thrombocytopenia (79 percent), abnormal liver function results (74 percent), neutropenia (67 percent), fatigue (66 percent), nausea (61 percent), anemia (55 percent), and headache (43 percent). The incidence of grade 3/4 side effects was primarily hematological with imatinib (neutropenia 14 percent and thrombocytopenia 8 percent) whereas interferon plus cytarabine included fatigue (24 percent) and hematological (neutropenia 25 percent and thrombocytopenia 17 percent). The incidence of side effects increased with imatinib dose and phase of illness, with hematologic side effects particularly increasing with advancing phases of illness.

In addition to the adverse events commonly described across this group of studies, four individual reports of adverse events were identified. Valeyrie and colleagues prospectively followed 54 patients started on imatinib 94 Eighty-nine percent experienced at least one cutaneous reaction; 67 percent had rashes, 65 percent edema and 41 percent pruritis. Six percent had severe enough rash to discontinue therapy either temporarily or permanently. The rate of rash increased with imatinib dose. In a similar study of 78 patients by Drummond et al., 12 percent of patients had rashes that could be directly attributed to imatinib.92 Steegmann reported a prospective study of gamma globulin levels in 36 patients receiving imatinib for CML when resistant to or intolerant of interferon. Low serum IgG, IgA, and IgM levels were identified in 28 percent, 14 percent and 22 percent of patients, respectively.93 Finally, Al-Ali and colleagues identified that imatinib caused elevated creatinine kinase (CK) levels of >50 percent above baseline in 81% of the 113 patient cohort studied; elevation was highest for those who reported cramps or myalgias.95 Patients whose CK levels were elevated after 6 months of imatinib had higher rates of Major CR (p=0.048).

Table 10 Adverse events

Phase of CML | | Chronic phase - newly diagnosed | | | | | | | Chronic phase - interferon resistant or refractory
First Author, Year | | Obrien 51 | | | | Kantarjian 55 | Kantarjian 56 | | Drucker 28 | | | | | | | | | Le Coutre 66 | Rosti 69 | | | Kantarjian, Cortes 65
First Author, Year | | Obrien 51 | | | | Kantarjian 55 | Kantarjian 56 | | | | | | | | | | | Le Coutre 66 | Rosti 69 | | | Kantarjian, Cortes 65
Drug / dosage | | imatinib | IFN/AraC | imatinib | IFN/AraC | Varied Doses | 800mg/d | | 25–140mg/d | | 200–300mg/d | | 350–500mg/d | | 600–1000mg | | total | % AE's related to Imatimib # of pts with event | # of AE's | | | Median Follow-up = 45 Months
n | | n=551 | n=553 | n=551 | n=553 | Varied Doses | n=114 | | n=14 | | n=23 | | n=18 | | n=28 | | n=83 | % AE's related to Imatimib # of pts with event | # of AE's | | | n=261
constituitional | | | | | | | | | | | | | | | | | | | 158 | 45 | 9
edema or fluid retention | | | | | | | 1% | 0% | 25% | 0% | 27% | 0% | 40% | 0% | 66% | 8% | 39% | | 77 | 14 | 2 | 0%
superficial edema | | 56% | 9% | 0.9% | 0.6% | | | | | | | | | | | | | 46%
periorbital
leg
face
othersite
eyelid
nausea | | 44% | 61% | 0.7% | 5.1% | | | | 25% | 0% | 36% | 0% | 60% | 0% | 71% | 0% | 43% | 5.1%
nausea/vomiting | | | | | | | 1% | 0% | | | | | | | | | | | | | | 0%
diarrhea | | 33% | 42% | 1.8% | 3.2% | | 1% | 0% | 17% | 0% | 5% | 0% | 40% | 0% | 46% | 4% | 25% | | | | | 0%
myalgia or musculoskeletal pain | | 1% | 1% | 1.5/2.7% | 1.0% | 0.02 | 3% | 2% | 25% | 0% | 63% | 0% | 40% | 7% | 34% | 17% | 41% | | | | | 1%
mucscle cramps | | 38% | 11% | 1.3% | 0.2% | | | | | | | | | | | | | 25.6% | | | | 0%
fatigue | | 35% | 66% | 1.1% | 24.4% | 0.02 | 1% | 2% | 17% | 0% | 27% | 0% | 13% | 0% | 29% | 4% | 20%
dermatitis or rash | | 34% | 25% | 2.0% | 2.3% | 0.06 | 6% | 6% | 8% | 0% | 20% | 0% | 13% | 0% | 34% | 4% | 19% | 15.4% | 47 | 21 | 4 | 2%
headache | | 31% | 43% | 0.4% | 3.2%
abdominal pain | | 2% | 25% | 2.4% | 3.9%
flatulence
vomiting | | 17% | 27% | 1.5% | 3.4% | | | | 0% | 0% | 16% | 0% | 13% | 0% | 41% | 0% | 18%
hemorrhage | | 21% | 21% | 0.7% | 1.5% | | | | | | | | | | | | | | 27 | 5 | 2*
tumor hemorrhage
cerebral hemorrhage
upper GI tract
dyspepsia | | 16% | 9% | 0.0% | 0.8% | | | | 17% | 0% | 16% | 0% | 34% | 0% | 20% | 0% | 18%
increased lacrimation
loose stools
taste disturbance
neutropenia | | 61% | 67% | 14.3% | 25.0% | | 36% | 20% | 0% | 0% | 11% | 5% | 7% | 7% | 0% | 29% | 14% | 8.0%
abdominal distension
abnormal liver-function results | | 43% | 74% | 5% | 7% | 4% | 7% | 10% | | | | | | | | | | | nr | 9 | 9
leukopenia
arthralgia | | | | | | | | | 0% | 0% | 5% | 0% | 7% | 0% | 34% | 4% | 13%
paresthesia
esophageal reflux
pruritus | | 7% | 12% | 0.2% | 0.2%
pain
blurred vision
photosensitivity
nasopharyngitis | | 22% | 8% | 0.0% | 0.2%
pyrexia | | 13% | 39% | 0.7% | 2.8%
insomnia | | 12% | 19% | 0.0% | 2.3%
upper respiratory tract infection | | 15% | 8% | 0.2% | 0.4%
granulocytopenia | | | | | | 20% | | | | | | | | | | | | | | | | 62%
thrombocytopenia | | 57% | 79% | 8% | 17% | 8% | 25% | 12% | 0% | 0% | 5% | 0% | 13% | 7% | 8% | 29% | 16% | 41.0% | | | | 22%
anemia | | 45% | 55% | 3% | 4% | 8% | 10% | 4% | | | | | | | | | | 12.8% | | | | 14%
GI symptoms | | | | | | | | | | | | | | | | | | | 125 | 24 | 0
weight increase
cough | | 15% | 22% | 0.2% | 0.6%
dyspnea | | 7% | 14% | 1.5% | 1.5%
anorexia | | 5% | 32% | 0.0% | 2.4%
constipation | | 9% | 14% | 0.7% | 0.2%
nasopharingitis
night sweats | | 7% | 16% | 0.2% | 0.4%
epitaxis
hypokalemia
petechiae
pneumonia
weakness
asthenia | | 6% | 19% | 0.2% | 4%
mucositis
neuro symptoms | | | | | | | | | | | | | | | | | | | 8 | 8 | 0
cardiac | | | | | | | 4% | 2% | | | | | | | | | | | | | | 0.8%
bone or joint aches | | 28% | 40% | 2.4% | 7% | | | | | | | | | | | | | 2.6% | | | | 1%
infection | | | | | | | | | | | | | | | | | | | 33 | 12 | 0
weight gain | | 13% | 2% | 0.9% | 0.2% | | | | | | | | | | | | | 12.8%
dizziness | | 15% | 24% | 0.9% | 3.4%
prolonged wound healing | | | | | | | | | | | | | | | | | | 2.6%
pharyngolaryngeal pain | | 16% | 13% | 0.2% | 0.2%
depression | | 10% | 36% | 0.4% | 13% | | | | | | | | | | | | | | | | | 0.8%
anxiety | | 7% | 11% | 0.2% | 3%
rigors | | 7% | 34% | 0.0% | 0.8%
influenza like illness | | 7% | 19% | 0.0% | 0.8%
alopecia | | 4% | 22% | 0.0% | 0.6%
increased sweating | | 4% | 15% | 0.0% | 0.4%
weight loss | | 3% | 17% | 0.2% | 1.3%
stomatitis | | 3% | 12% | 0.0% | 0.2%
dry mouth | | 2% | 10% | 0.0% | 0.2%
mucosal inflammation | | 1% | 10% | 0.0% | 3.2%
psychiatric | | | | | | | | | | | | | | | | | | | 10 | 8 | 0
cardiovascular | | | | | | | | | | | | | | | | | | | 10 | 4 | 3*
other | | | | | | | | | | | | | | | | | | | 36 | 6 | 2**
hematologic | | | | | | | | | | | | | | | | | | | ade 4 AE's which were recorded

Phase of CML | | Chronic phase - previous stem cell transplant/heavily pretreated | | | Mixed phased | | | | | | | | | | | | | Accelerated phase
First Author, Year | | Cervantes 28 | | Kantarjian 72 | Cohen 76 | | | | | | | LaHaye 79 | | | | | | Talpaz 81
Drug / dosage | | ASCT | no ASCT | | phase 1 | phase 2 | | | | | | LaHaye 79 | | | | | | Talpaz 81
| | | | | phase 1 | CML-BC | | CML-AP | | CML-CP IFN failures | | CML-CP | | | | CML-AP | CML-BC
n | | | | varied doses | phase 1 | n=260 600mg n=223 400mg n=37 | | 600mg n=158 400mg n=77 | | n=532 400mg | | n=139 | | n=80 | | n=76 | | n=235 events reported in atleast 5% of pts | | all pts n=235 | 400mg n=77 | 600mg n=158
constituitional
edema or fluid retention | | 21% | | 10% | 39% | 67% | 10% | 68% | 6% | 52% | 2% | | | | | | | 64% | 3%
superficial edema | | | | | | 63% | 5% | 66% | 4% | 51% | 1%
periorbital | | | | 7%
leg | | | | 7% | | | | | | | | 29% | 0% | 36% | | 29%
face
othersite | | | | 4% | | 16% | 6% | 9% | 3% | 2% | 1%
eyelid | | | | | | | | | | | | 46% | 0% | 38% | | 45%
nausea | | | | | 43% | 68% | 3% | 68% | 5% | 55% | 2% | 29% | 1% | 31% | | 47% | | 65% | 3%
nausea/vomiting | | | | 4%
diarrhea | | | | 0% | 25% | 39% | 3% | 49% | 4% | 33% | 9% | | | | | | | 37% | 0%
myalgia or musculoskeletal
pain | | | | 4% | 41% | 37% | 8% | 39% | 7% | 27% | 1% | | | | | | | 13% | 1%
mucscle cramps | | 0.15 | | | | 25% | 0% | 34% | 0% | 46% | 1% | 53% | 0% | 39% | | 32% | | 32% | 0%
fatigue | | | | | | 24% | 2% | 33% | 3% | 25% | 0% | | | | | | | 11% | 3%
dermatitis or rash | | 0.03 | 11% GVHD related | | | 32% | 4% | 39% | 4% | 36% | 3% | 18% | 5% | 24% | | 26% | | 22% | 1%
headache | | | | | | 24% | 4% | 26% | 2% | 28% | 0% | | | | | | | 13% | 1%
abdominal pain | | | | | | 23% | 5% | 26% | 2% | 20% | 0%
flatulence
vomiting | | | | | | 49% | 3% | 54% | 3% | 28% | 1% | | | | | | | 49% | 1%
hemorrhage | | | | | | 48% | 16% | 35% | 8% | 13% | 0% | | | | | | | 12% | 2%
tumor hemorrhage
cerebral hemorrhage | | | | | | 4% | 2% | 1% | 0% | 0% | 0%
upper GI tract | | | | | | 5% | 2% | 3% | 1% | 0% | 0%
dyspepsia | | | | | | 9% | 0% | 19% | 0% | 18% | 0% | | | | | | | 16% | 0%
increased lacrimation
loose stools | | | | | | | | | | | | 24% | 0% | 20% | | 29%
taste disturbance
neutropenia | | | | | | | | | | | | | 19% | | 48% | | 57% | | | 22%/35%21%/35%25%/35%
abdominal distension
abnormal liver-function results | | 3% | | 18% | %(gd 2 or >)
leukopenia | | | | | | | | | | | | | 14% | | 36% | | 54% | | | 33%/14%27%/18%35%/13%
arthralgia | | | | | | 21% | 3% | 26% | 5% | 24% | 1% | | | | | | | 12% | 3%
paresthesia
esophageal reflux
pruritus | | | | | | 6% | 1% | 10% | 0% | 9% | 1% | | | | | | | 9% | 0.4%
pain | | | | | | | | | | | | | | | | | | 11% | 1%
blurred vision
photosensitivity
nasopharyngitis
pyrexia | | | | 4% | | 38% | 7% | 35% | 7% | 14% | 1%
insomnia
upper respiratory tract infection
granulocytopenia | | 33% | 32% | 43%
thrombocytopenia | | 27% | 17% | 27% | | | | | | | | | | | 16% | 40% | 64% | | | 31%/12%30%/14%32%/11%
anemia | | 12% | 5% | | | | | | | | | | | | 6% | 39% | 41% | | | 33%/6% 35%/9%32%/15%
GI symptoms | | 18% | | | | | | | | | | | | | | | | 7% | 0.4%
weight increase | | | | | | 4% | 0% | 6% | 1% | 14% | 2%
cough | | | | | | 12% | 1% | 22% | 1% | 9% | 0%
dyspnea | | | | | | 12% | 4% | 16% | 5% | 5% | 0%
anorexia | | | | | | 10% | 2% | 14% | 1% | 3% | 0% | | | | | | | 8% | 1%
constipation | | | | | | 13% | 1% | 13% | 1% | 4% | 0%
nasopharingitis | | | | | | 5% | 0% | 10% | 0% | 9% | 0%
night sweats | | | | | | 10% | 1% | 10% | 1% | 8% | 0%
epitaxis | | | | | | 12% | 3% | 9% | 0% | 3% | 0%
hypokalemia | | | | | | 12% | 3% | 9% | 1% | 2% | 0%
petechiae | | | | | | 10% | 1% | 4% | 1% | 1% | 0%
pneumonia | | | | | | 10% | 5% | 7% | 5% | 1% | 0%
weakness | | | | | | 10% | 3% | 8% | 2% | 5% | 0%
asthenia
mucositis
neuro symptoms
cardiac
bone or joint aches | | | | 7%
infection | | | | 4%
weight gain | | | | | | | | | | | | | | | | | | 11% | 1%
dizziness
prolonged wound healing
pharyngolaryngeal pain
depression
anxiety
rigors
influenza like illness
alopecia
increased sweating
weight loss
stomatitis
dry mouth
mucosal inflammation
psychiatric
cardiovascular
other
hematologic | | | | | | | | | | | | | | | | | | 9% | 0.4%

Phase of CML | | Blastic phase | | | | | | | | | | | imatinib efficacy/other
First Author, Year | | Drucker 59 | | | | | | | Sawyers 85 | | Sureda 86 | | Gardembas 30
Drug / dosage | | 300mg/d | | 400–500mg/d | | 600–1000mg/d | | total | | | | | 400mg combined with Ara-C
n | | n=8 | | n=17 | | n=33 | | n=58 | n=260 | | n=30 | | n=30 | n=16
constituitional
edema or fluid retention | | 43% | 21% | 31% | 10% | 78% | 10% | 41% | 57% | 6% | 40%
superficial edema | | | | | | | | | 55% | 4% | | | 50% | 0%
periorbital
leg
face
othersite | | | | | | | | | 9% | 3%
eyelid
nausea | | 43% | 21% | 60.0% | 10.0% | 95% | 21% | 55% | 63% | 2% | 30% | 3% | 83% | 0%
nausea/vomiting
diarrhea | | 0% | 0% | 21.0% | 0.0% | 41% | 0% | 17% | 24% | 1% | 23% | | 40% | 0%
myalgia or musculoskeletal pain | | 43% | 0% | 31.0% | 0.0% | 36% | 0% | 21% | 12% | 1% | 3% | 3% | 50% | 0%
mucscle cramps | | | | | | | | | 25% | 1% | | | 37% | 0%
fatigue | | 21% | 0% | 41.0% | 0.0% | 5% | 0% | 10% | 8% | 2% | 37%
dermatitis or rash | | 0% | 0% | 31.0% | 0.0% | 26% | 10% | 17% | 23% | 4% | | 6% | 23% | 0%
headache | | | | | | | | | 10% | 1% | | | 30% | 0%
abdominal pain | | | | | | | | | 27% | 1% | | | 53% | 10%
flatulence
vomiting | | 66% | 0% | 60.0% | 10.0% | 57% | 16% | 41% | 44% | 1% | 23% | | 63% | 13%
hemorrhage | | | | | | | | | 10% | 2%
tumor hemorrhage
cerebral hemorrhage
upper GI tract
dyspepsia | | | | | | | | | 7% | 0%
increased lacrimation
loose stools
taste disturbance
neutropenia | | | | | | | | | | 16/48% | 37% | 20% | 53% | 27%
abdominal distension
abnormal liver-function results | | | | | | | | | | | 14% | 6%
leukopenia
arthralgia | | | | | | | | | 8% | 1% | 13%
paresthesia
esophageal reflux
pruritus | | | | | | | | | | | | | 13% | 0%
pain
blurred vision
photosensitivity
nasopharyngitis | | | | | | | | | | | | | 27% | 0%
pyrexia
insomnia
upper respiratory tract infection
granulocytopenia
thrombocytopenia | | | | | | | | | 29/33% | | 23% | 20% | 50% | 37%
anemia | | | | | | | | | 41/11% | | | | 10% | 7%
GI symptoms
weight increase
cough
dyspnea
anorexia | | 21% | 0 | 33% | 0 | 10% | 0 | 10% | | | | | 13% | 0%
constipation
nasopharingitis
night sweats
epitaxis
hypokalemia
petechiae
pneumonia
weakness
asthenia | | | | | | | | | | | | | 21% | 2%
mucositis | | | | | | | | | | | | | 13% | 0%
neuro symptoms | | | | | | | | | | | | | 3% | 0%
cardiac
bone or joint aches
infection
weight gain
dizziness
prolonged wound healing
pharyngolaryngeal pain
depression
anxiety
rigors
influenza like illness
alopecia
increased sweating
weight loss
stomatitis
dry mouth
mucosal inflammation
psychiatric
cardiovascular
other
hematologic | | | | | | | | | | | 67% | 23%

## Predictors

Ideally, treatment is matched to those patients most likely to respond to that treatment. Certain clinical and molecular characteristics can be used to predict which patients with CML are more or less likely to respond to imatinib. These predictors of response to imatinib are distinct from the disease characteristics that correlate with prognosis irrespective of treatment plan. For example, the most important prognostic factor is the phase of disease. Some prognostic factors are also associated with response to treatment. Clinical characteristics predicting response were presented in the Efficacy section and included:

▪ phase of disease (CP, AP and BP; early vs. late CP);
▪ previous treatment before imatinib (interferon, stem cell transplantation);
▪ reason that previous treatments were discontinued (resistant, refractory, intolerant); and,
▪ dose.

Many authors have reviewed the correlation between clinical prognostic factors (e.g., splenomegaly, percentage of blasts in the peripheral blood, platelet count) and tumor response or survival with imatinib. As expected, most of the known prognostic factors can be used to identify high risk and low risk patients in the setting of imatinib therapy in a similar manner to other treatment settings. A full review of the hazard ratios for these clinical prognostic factors is outside the scope of this review. Here we concentrate on molecular factors that predict response to imatinib and are likely to be related to the targeted action of the drug.

The molecular predictors can be arbitrarily divided into four groups. The first three groups are based upon whether the assessment focuses on genetic material (DNA), production of the RNA message, or the tyrosine kinase protein and its interaction with imatinib. A fourth group includes other miscellaneous predictors. Group 1 includes DNA predictors are related to the formation of Ph, the evidence of impact of imatinib on the Ph, the accumulation of other DNA abnormalities within the CML cells, or genetic profiling to predict imatinib responders. Group 2 includes RNA predictors that relate to the production of the BCR-ABL mRNA transcripts including trends in production over time. Group 3 relates to changes in the tyrosine kinase protein that influence the activity of imatinib. Group 4 includes other related predictors that were identified in this review such as bone marrow cellularity and myelosuppresssion. These groups can be further divided into characteristics identified at the start of imatinib therapy and characteristics that can be evaluated during therapy to predict response (subclassification A or B).

Assessment of study quality is reviewed in Chapter 2. Quality scores reflect study reporting quality from a clinical research standpoint, not the quality of the basic science. In a broad review of the literature such as this one, it is difficult to determine which predictors have been exhaustively scientifically validated and which ones are only investigational. The volume of studies citing an individual predictor is used as a proxy indicator. These tables have been arranged so that potential predictors with a large number of supporting studies are cited at the beginning of the tables and emerging predictors are cited at the end.

### Molecular predictors: Group 1A--DNA factors at the start of imatinib therapy

Ph+ cells measured during cytogenetic analysis is a measurement of burden of disease. This is represented in terms of “percentage of Ph+ metaphases” at the start of imatinib therapy. Five studies evaluated the relationship between this predictor and tumor response, progression, or survival. There were significantly more patients with a Major CR when <90 percent of metaphases where Ph+ at the start of therapy.1, 2 A similar trend for survival was seen, but not statistically significant.1 There were significantly more patients with a Complete CR when <100 percent of metaphases where Ph+ at the start of therapy; overall survival was longer too.75 For those patients increased to 800 mg of imatinib due to disease resistance at 400 mg, complete and partial cytogenetic response were again more likely if Ph+ cells represented <100 percent of metaphases.74 In terms of disease progression, there was not a statistically significant relationship between CML hematologic relapse and those patients with >98 percent Ph+ metaphases at the beginning of therapy, but the trend for relapse followed that previously seen.96 These secondary analyses were predominantly from studies of patients with CML in chronic phase that is resistant or refractory to interferon (CP-IFN-r); one study included other CP patients and AP patients.1 In general, patients with a smaller burden of disease at the start of imatinib therapy were more likely to have a Major CR, Complete CR, and/or improved overall survival.

Chromosomal abnormalities in addition to the Ph have been repeatedly investigated as a potential prognostic and therapeutic predictor in CML. Cytogenetic abnormalities have been investigated both at the time of initial diagnosis and with clinical disease progression (e.g., from chronic to accelerated phase). The language that various authors use to describe this process is imprecise, including descriptions of “other chromosomal abnormalities,” “complex cytogenetics,” and “cytogenetic clonal evolution”. Overall, the most common terminology in “clonal evolution” and therefore this grouping will be used to represent this category of predictive markers.

Clonal evolution at the time of initial diagnosis may be a marker for more advanced or aggressive disease. Indeed, larger studies of patients in AP and BP supported that clonal evolution at baseline predicted poorer survival (p<0.005)3, 4 and likely predicted disease progression (p=0.086).87 Smaller studies did not support these findings.67, 90 Cytogenetic clonal evolution is often a hallmark of CML as it progresses from chronic to more advanced phases. Similar to phase being a clinical predictor of response to imatinib, clonal evolution may be a molecular predictor. Ten studies including patients in CP and CP-IFN-r considered cytogenetic clonal evolution as a predictor of tumor response, although it was likely that these studies reflected multiple presentations of the same patient populations. Taken together these studies suggested that cytogenetic clonal evolution inconsistently predicted disease response,1, 2, 70, 75 but was a major predictor of the risk of disease relapse (relative risks (RR) reported 4.34, 4.912, and 14.8)96, 97, 99 and survival.1, 44, 70, 72, 75

CD34 is an antigen that is selectively expressed on myeloid and lymphoid hematopoetic progenitor cells. Marin and Elliot both presented abstracts that indicated that the percent of CD34+ cells in the bone marrow in CML correlated with tumor response.100, 101

Variant Ph translocations occur in up to 10 percent of cases of CML. The variant Ph may lead to variant BCR-ABL tyrosine kinase proteins and therefore affect imatinib’s efficacy. Prior to the era of imatinib, variant Ph was not associated with prognosis except perhaps abnormalities involving chromosome 17.^49^ In an analysis that included patients in CP and AP, El-Zamaity and colleagues did not identify a significantly shorter duration of response with variant Ph as compared to other patients with CML.97

Deletions of the resultant DNA on chromosome 9 can be seen in up to 15 percent of cases of CML.50 Chromosome 9 deletions are known to negatively affect prognosis, decreasing survival by up to 20 percent at 5 years.53, 54 These studies were conducted predominantly in patients on interferon-based therapies.50 In the setting of imatinib, chromosome 9 deletions lead to poorer PFS in CP, AP and BP settings (p=0.02).51 Another study found no differences in major CR or complete CR in CP patients.144 Overall survival was not significantly different in either study with median follow-up of 48 months. Longer periods of followup may be needed.

Investigations of genetic patterns are underway. A number of genes are known to be related to drug resistance and programmed cell death (apoptosis) in leukemic cells. Evaluation of gene expression suggested that MRP-1 was overexpressed in blast crisis CML, and that MRP-1 overexpression was significantly correlated with poor tumor response to imatinib.102 Using gene microarray techniques, McLean and colleagues identified a genomic profile and microarray pattern characteristic of tumor response in CP CML. Patients whose CML met this ideal microarray profile had a substantially greater likelihood of Complete CR (odd ratio (OR) 200, 95% CI 19-3096) and Major CR (OR 19.9, 95% CI 6–67).103

In summary, DNA factors at the start of imatinib therapy that predict poorer tumor response and/or survival include the following:

▪ 90–100 percent of metaphases are Ph+ at the start of imatinib;
▪ Clonal evolution in AP or BP;
▪ Clonal evolution in CP (predicts risk of relapse and poorer survival);
▪ Higher percentage of CD34+ cells in the bone marrow;
▪ Chromosome 9 deletions; and,
▪ Genetic profiles.

Table 11 Tumor characteristics predictive of disease response or survival: Group 1A -- DNA factors at the start of imatinib therapy

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
% of Ph+ metaphases at the start of therapy | Cortes, Talpaz, et al.., 2003^1^ (quality = 6/6) CP & AP | Relationship to Major CR: Ph+ <90%: N= 295 91% p<0.0001 Ph+ >90%: N = 270 54% | Relationship to survival: Ph+ <90% N= 295 96% p=0.08 Ph+ >90% N = 270 81%
% of Ph+ metaphases at the start of therapy | Kantarjian, Sawyers, et al., 2002^2^ (quality = 6/6) CP-IFN-r | Relationship to Major CR: Ph+ <90%: N= 55 89% p<0.001 Ph+ >90%: N = 378 56%
% of Ph+ metaphases at the start of therapy | Marin, Goldman, et al., 2003^74^ (quality 1/5) CP-IFN-r | Predictor of response to I at 800 mg (when resistant to I at 400 mg): Ph+ < 100%: N=18 28% CCR, 16% MCR + minorCR Ph+ = 100%: N=18 0% CCR, 6% MCR + minorCR p<0.05
% of Ph+ metaphases at the start of therapy | Marin, Marktel, Bua, et al., 2003^75^ (quality 2/5) CP-IFN-r | Relationship to CCR: Ph+ < 100%: N= 20 80% p=<0.0001 Ph+ = 100%: N = 122 21% | Relationship to OS: Ph+ < 100%: N= 20 100% p=<0.02 Ph+ = 100%: N = 122 68%
% of Ph+ metaphases at the start of therapy | O’Dwyer, 2004^96^ (quality 2/5) CP-IFN-r | Relationship to hematologic relapse: Ph+ <99%: N= 20 2% p=0.2478 Ph+ = 99%+: N = 118 17%
Clonal evolution (AP and BP/BC) | Kantarjian, Cortes, 2002^90^ (quality 5/6) BP | Relationship to Major CR: None: N = 28 64% p=0.15 Clonal evolution: N = 43 47% | None: N = 28 median survival = 7.5 mo Clonal evolution: N = 43 median survival = 4.5 mo p=0.49
Clonal evolution (AP and BP/BC) | Sawyers, 2002^3^ quality 5/6) BP | | None: N = 67 median survival = 10.5 mo Clonal evolution: N = 111 median survival = 5.5 mo p=0.003
Clonal evolution (AP and BP/BC) | Sureda, 2003^4^ (quality 4/5) BC | | Ph+ only: N= 18 1-yr OS = 57% (SD 18%) Clonal evolution: N = 12 1-yr OS = 0% p=0.0043
Clonal evolution (AP and BP/BC) | Talpaz, 2002^87^ (quality 5/6) AP | Relationship to disease progression: None: N = 100 38% p=0.086 Clonal evolution: N = 60 50%
Cyotgenetic clonal evolution (likely overlapping patient populations) | Braziel, 2002^67^ (quality = 3/6) CP-IFN-r | Presence or absence of clonal evolution not related to response (3 of 19 pts with complex cyto–were distributed among three response groups)
Cyotgenetic clonal evolution (likely overlapping patient populations) | Cortes, Talpaz, et al.., 2003^1^ (quality = 6/6) CP | Relationship to Major CR: None: N= 295 65% p=0.1 Clonal evolution: N = 270 54% | Relationship to survival: None: N= 295 92% p=0.002 Clonal evolution: N = 270 77%
Cyotgenetic clonal evolution (likely overlapping patient populations) | El-Zimaity, 2004^97^ (quality = 3/6) CP & AP | Shorter duration of response RR 4.34 (SE 0.47) p=0.002
Cyotgenetic clonal evolution (likely overlapping patient populations) | Kantarjian, Sawyers, et al., 2002^2^ (quality = 6/6) BP | Relationship to Major CR: None: N = 379 61% p=0.18 Clonal evolution: N = 54 52%
Cyotgenetic clonal evolution (likely overlapping patient populations) | Karntarjian, Talpaz, et al., 2002^70^ (quality 5/5) CP-IFN-r | Relationship to Major CR: None: N= 222 65% p=0.02 Clonal evolution: N = 27 41% | Relationship to survival: None: N= 222 98% p<0.01 Clonal evolution: N = 27 84%
Cyotgenetic clonal evolution (likely overlapping patient populations) | Kantarjian, O’Brien, 2004[Kantarjian, 2004 #151 (quality 5/6) CP-IFN-r | | None: 2 yr survival = 87% 4 yr survival = 66% Clonal evolution: 2 yr survival = 66% 4 yr survival = 55% p=0.05
Cyotgenetic clonal evolution (likely overlapping patient populations) | Kantarjian, O’Brien, 2003^98^ (quality 3/6) CP-new diagnosis | | Relationship to estimated 5-yr survival: None: N= 779 66% p=0.95 Clonal evolution: N = 58 65% (only 187 received I; others = IFN)
Cyotgenetic clonal evolution (likely overlapping patient populations) | Karntarjian, Cortes, et al., 2004^72^ (quality 5/6) CP-IFN-r | | Relationship between baseline clonal evolution and 4-yr survival: None: N= 237 88% p=0.007 Clonal evolution: N = 24 69%
Cyotgenetic clonal evolution (likely overlapping patient populations) | Marin, Marktel, et al., 2003^75^ (quality 2/5) CP | Relationship to CCR: None: N= 24 33% p=0.41 Clonal evolution: N = 31 24% | Relationship to OS: None: N= 111 81% p<0.0001 Clonal evolution: N = 31 32%
Cyotgenetic clonal evolution (likely overlapping patient populations) | Marktel, 2003^99^ (quality 5/6) CP-IFN-r | Relationship to PFS at 18 mos: None: N= 50 94% p<0.0001: Clonal evolution: N = 10 34% Confirmed in multivariate model (RR 14.8, CI 2.8 76.6)
Cyotgenetic clonal evolution (likely overlapping patient populations) | O’Dwyer, 2004^96^ (quality 2/5) CP-IFN-r | Relationship to hematologic relapse: None: N= 119 9% p<0.0001 Clonal evolution: N = 22 50% HR 4.912 (CI 1.944–12.409)
CD34+ cells in the bone marrow | *Marin, 2004^100^ (quality *) CP | Relationship to PFS: CD34+ % of BM cells <2% (N=44)–PFS @ 3-yr = 77% CD34+ % of BM cells >2% (N=14)–PFS @ 3-yr = 36% p=0.006
CD34+ cells in the bone marrow | *Elliot, 2004^101^ (quality *) phase unclear | CD34+ cells/10hpf predicts CCR
Variant Ph translocations | El-Zimaity, 2004^97^ (quality = 3/6) CP & AP | Shorter duration of response RR 1.33 (SE 0.76) p=0.71
Chromosome 9 deletions | Huntly, 2003^51^ (quality = 2/6) CP-new diagnosis, AP, BP | Progression free survival for CP patients with (N = 35) and those without deletions (N=172) is significantly different; those with deletions did worse. p=0.02 Progression free survival for AP + BP patients with (N = 15) and those without deletions (N=106) is significantly different; those with deletions did worse. p=0.02 | Overall survival for patients with (n = 54) and those without deletions (n=297) not significantly different; median follow up 48 months. p=0.18
Genes known to be related to apoptosis and drug resistance in leukemia cells | Lange, 2003^102^ (quality 4/6) BC | 8 candidate genes studied via Q-RT-PCR; when compared to healthy controls, BCL-XL, MDR-1, BAX, MRP-1 and survivin is overexpressed in BC (all p<0.05) MDM-2 is underexpressed (p=0.001) The only candidate gene correlated with tumor response was MRP-1 (med <24 10/16 responses, >24 5/21, p=0.018; multivariate model OR of no response with high MRP-1 = 14.4 (p=0.011)
Genomic microarrays | McLean103 (quality 5/6) CP | Used microarray technology to evaluate the signature of >1000 genes and develop a genomic expression profile that is characteristic of CR in CP-CML Pt met ideal microarray profile: OR for CCR = 200 (19-3096; N=66) OR for MCR = 19.9 (6-67; N=90)

Abbreviations: * abstract; AP = Accelerated phase; BC = Blast crisis; BM = bone marrow; BP = Blastic phase; CI = 95% confidence interval; CML = Chronic myelogenous leukemia; CP = chronic phase; CR = cytogenetic response; CCR = complete cytogenetic response; cyto = cytogenetics; hpf = high powered fields; HR = Hazard Ratio; I = Imatinib; IFN = Interferon; M = Male; MCR = major molecular response; N = Number; NR = not reported; OR = Odds ratio; OS = Overall Survival; PFS = progression-free survival; Ph+ = Philadelphia chromosome positive; pt(s)=patient(s); RR = relative risk;

### Molecular predictors: Group 1B—DNA factors monitored during imatinib therapy

Cytogenetic response (CR) is the most commonly used surrogate marker of tumor response for CML. Its relationship to PFS and OS in the setting of imatinib therapy has been confirmed by at least seven studies involving all phases of CML.8, 62, 68, 72, 75, 83, 96 Timing of the CR is also important. Across the analyses that evaluated the time course of the CR, CR by 3 or 6 months strongly predicted PFS and OS. 62, 72, 75 In the only study that compared timepoints, partial CR by 6 months was most predictive of survival72

Similarly, the degree of reduction in CD34+ cells in the bone marrow can be considered another surrogate marker of tumor response. Marin demonstrated that the degree of reduction of CD34+ cells in CML in the setting of imatinib treatment correlated with progression free survival (RR 0.88, 95 percent CI 0.53–0.93).100 This is consistent with imatinib decreasing the percentage of blasts and normalization to a CHR.

In summary, DNA factors monitored during therapy that predict [underlined: better] tumor response and/or survival include the following:

▪ Cytogenetic response; and,
▪ Degree of reduction of CD34+ cells in the bone marrow.

Table 12 Tumor characteristics predictive of disease response or survival: Group 1B—DNA factors evaluated during imatinib therapy

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
Cytogenetic response to imatinib | Marin, Marktel, Szydlo, et al., 2003^68^ (quality 5/5) CP-IFN-r | Achieved at least a minor CR with I: RR for PFS = 0.09 (CI 0.03–0.25, p<0.0001) No cytogenetic response with I: RR for OS = 1.94 (CI 1.22–3.01, p=0.0053) | Achieved at least a minor CR with I: RR for OS = 0.13 (CI 0.05–0.39, p=0.0002) No cytogenetic response with I: RR for OS = 1.69 (CI 1.09–2.64, p=0.02) Adjusted probabilities of OS at 8 years were 78% (CI 51–93%) for responders, 23% (CI 18–29%) for IFN refractory historical controls not getting I, and 6% (CI 2–17%) for non-responders
Cytogenetic response to imatinib | O’Dwyer, 2004^96^ (quality 2/5) CP-IFN-r | Relationship of MCR to hemotologic relapse: No MCR: N= 77 26% p=0.0339 MCR: N = 64 3% HR 0.193 (CI 0.042–0.883)
Cytogenetic response to imatinib | Rosti, 2004^8^ (quality 4/5) CP | | Achieved at least a MCR with I: OS estimated from KM at 26 mo median f/u No MCR = 92% p=0.037 MCR = 97%
Cytogenetic response to imatinib | Silver, 2004^83^ (quality *) CP, AP, BP | | AP: Relationship between MCR at 3 mo and 3-yr survival: MCR at 3 mo - 85% 3-yr OS No MCR - 52% 3-yr OS p<0.001 CP: Relationship between at least a MinorCR at 6 mos and 3-yr survival: MinorCR at 6 mo - 96% 3-yr OS No MinorCR at 6 mo - 86% 3-yr OS p<0.001
Cytogenetic response to imatinib | Karntarjian, Cortes, et al., 2004^72^ (quality 5/6) CP-IFN-r | Relationship between Major or Minor CR and 4-yr PFS: CR = 93% No CR = 55% p<0.0001 Relationship between Major CR at 6 mo and 4-yr PFS: CR = 94% No CR = 51% p<0.0001 | Relationship between MCR or MinorCR and 4-yr OS: CR = 95% No CR = 72% p<0.0001 Relationship between MCR or MinorCR at 6 mo and 4-yr OS: CR = 96% No CR = 70% p<0.0001 In multivariate analysis, MinorCR or MCR at 3 and 6 mo predict survival (p=0.03 and 0.01, respectively).
Cytogenetic response to imatinib | *Guilhot, 2004^62^ (quality *) CP-new diagnosis Marin, Marktel, Bua, et al., 2003^75^ (quality 2/5) CP | Relationship between MCR at 6 mo and 30-mo PFS: MCR at 6 mo (n=407) - 97% No MCR at 6 mo (n=124) - 89% p<0.001 Relationship to PFS (described in terms of % of Ph+ metaphases at 3 months): Ph+ 0–65% (Minor CR + MCR): N= 52 83% p=<0.0001 Ph+ > 65% (No CR): N = 88 32% | Relationship between MCR at 6 mo and 30-mo OS: MCR at 6 mo (n=407) - 97% No MCR at 6 mo (n=124) - 92% p=0.0162 Relationship to OS: Ph+ 0–65%: N= 52 96% p=<0.0001 Ph+ > 65%: N = 88 52%
Change in CD34+ cells in the bone marrow | *Marin, 2004^100^ (quality *) CP | Degree of reduction of CD34+ cells–RR for PFS = 0.88 (CI 0.53–0.93) p=0.006

Abbreviations: *= abstract; AP = Accelerated phase; BP = Blastic phase; CI = 95% confidence interval; CP = Chronic phase; f/u = follow up; HR = Hazard Ratio I = Imatinib; IFN = Interferon; IFN-r = IFN refractory; K-M = Kaplan-Meier; OS = overall survival; EFS = event-free survival; M = Male; MCR = major molecular response; minorCR= minor molecular response; OS= Overall Survival; PFS = progression-free survival; pt(s)=patient(s); RR = relative risk

### Molecular predictors: Group 2–Production of the RNA message

All of the RNA factors identified related to quantification of BCR-ABL mRNA transcripts and evaluation of their time course using Q-RT-PCR. All phases of CML were studied. A decrease in mRNA transcripts with treatment is a “molecular response” (MR), and is a surrogate marker of CML tumor response. RNA factors can also be considered in terms of evaluation prior to initiation of imatinib therapy and then followup evaluation during treatment.

Nine studies support the association between MR and overall tumor response.5–12 An individual patient’s best MR predicts survival and those with very low levels of residual disease (median ratio <0.1 percent) have the more durable Complete CRs.10 Among all patients in the IRIS study who achieved a Complete CR, those who received imatinib had a greater MR than those who received interferon plus cytarabine (p=0.036).11

Response to imatinib is independent of BCR-ABL mRNA transcript number at the start of treatment.6, 55, 104 However, molecular monitoring during imatinib therapy is predictive of overall tumor response. Generally, this is considered in terms of transcript level or log reduction in transcript levels at 1, 3, 6, or 12 months. Median log reduction of > 2 at both 3 and 6 months was predictive of continued tumor response at 24 months.33 Median log reduction of > 3 at 12 months was also predictive of continued tumor response at 24 months.11 Similarly, when the BCR-ABL/ABL ratio is <50 percent at 4 weeks, the PFS at 500 days is 100 percent, vs. 45 percent for those who do not achieve a ratio of <50 percent.48 Based upon data from the IRIS study, BCR-ABL transcript levels did not decrease substantially after 24 months on imatinib treatment.8, 113 There are also substantially more IRIS patients that received imatinib with ≥3 log reductions in transcript levels than those who received interferon plus cytarabine.11

In summary, factors related to production of the RNA message that are monitored during therapy and predict [underlined: better] tumor response include the following:

▪ Molecular response;
▪ > 2 log reduction in BCR-ABL mRNA transcripts at 3 or 6 months;
▪ ≥ 3 log reduction in BCR-ABL mRNA transcripts at 12 months; and,
▪ BCR-ABL/ABL ratio <50 percent at 4 weeks.

Table 13 Tumor characteristics predictive of disease response or survival: Group 2–Production of the RNA message

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response
Molecular response as a marker of tumor response | Paschka, 2003^10^ (quality = 4/6) CP-IFN-R | Best individual molecular ratios in patients who achieved a MCR and subsequently relapsed were significantly higher than that of patients who remained in CCR, median f/u 13 mo (p=0.0017) BCR-ABL/ABL Median All pts = 0.086 (0–3.9) Relapse = 1.4 (0.013–7.8) Continuous CCR = 0.071 (0–3.9) All pt who achieved median ratio <0.1% are in CCR
Molecular response as a marker of tumor response | Müller, 2003^104^ (quality 5/6) CP-new Diagnosis | Median BCR-ABL/ABL ratio at start of I (N=98) was 51% (1–210%) Median for CR pts (N=85): 0.067% (0–5.7%) Median for PR pts (N=5): 1.4% (0.18–11%) Median for MinorR pts (N=7): 27% (6–69%) Median for pts in NR (N=2): 42% (38–45%)
Molecular response as a marker of tumor response | Hughes 2003 (quality = 6/6)11 CP- new diagnosis | Relationship between CCR and reduction in level of transcripts: I-treated in CCR (N=333): 2.5 log reduction IFN+cytarabine in CCR (N=37): 2.2 log reduction p=0.036
Molecular response as a marker of tumor response | Merx, 2002^105^ (quality = 5/5) CP-IFN-r | Median BCR-ABL/ABL ratio at start of I (N=120) was 67% (0.01–100%) Median for CR pts (N=50): 0.85% (0.018–21%) Median for PR pts (N=42): 6.7% (0.5–94%) Median for Minor R pts (N=33): 45% (6–100%) Median for NR pts (N=50): 46% (6–100%) CR to PR (p < 0.0001) PR and MinorR (p < 0.0001), MinorR and NR (p NS)
Molecular response as a marker of tumor response | Rosti, 2004^8^ (quality 4/5) CP-IFN-r | >2 log reduction in the BCR-ABL/B_2_ microglobulin transcript ratio in 76/85 (89%) pt in CCR with I and 0/23 (0%) pt in PCR
Molecular response as a marker of tumor response | Stentoft, 2001^7^ (quality 4/5) AP & CP | Longitudinal plots of BCR-ABL transcripts derived from blood and bone marrow samples correlate (i.e. peripheral blood assessments are adequate) On plots, 1 log reduction in BCR-ABL transcript levels correlate with CCR (strength of association not given
Molecular response as a marker of tumor response | Wu, 2002^6^ (quality 3/5) CP, AP & BC | Longitudinal plots of BCR-ABL transcript copy numbers correlate with cytogenetic response
Molecular response as a marker of tumor response | *Cortes, Talpaz, OBrien, Giles, et al., 2004^5^ (quality *) CP-new diagnosis | Relationship between increasing transcript levels and relapse at 24 mos: <0.05 increase–0/44 (0%) loss of CCR 0.05–1 increase–6/33 (18%) >1–5/11 (45%) p=0.0001
Molecular response as a marker of tumor response | Moravcova, 2004^9^ (quality 3/6) CP-IFN-r | 6/11 CP pts achieved CCR with rapid decrease in transcript 18-2600 fold at 6 mo, and 37-12500 fold at 12 mo; no BP or AP pt (0/8) showed this trend
Molecular response as a marker of tumor response | Karntarjian, Talpaz, et al., 2004^12^ (quality = 5/5) CP-IFN-r | If BCR-ABL/ABL is <0.05%, then all pt (N=71) had a CCR and none relapsed by 10 mo median f/u
Prognostic value of baseline transcript levels | Müller, 2003^104^ (quality 5/6) CP-new Diagnosis | Median BCR-ABL/ABL ratio at start of I (n=98) was 51% (1–210%) Response to I was independent of BCR-ABL level at start of therapy
Prognostic value of baseline transcript levels | Hochhaus, 2002^55^ (quality = 3/6) CP | Relationship between presence of higher ratio and resistance expressed as the ration of BCR-ABL/G6PD: Prior to Imatinib 4.6 % With Imatinib resistance 6.0% p=NS
Prognostic value of baseline transcript levels | Wu, 2002^6^ (quality 3/5) CP, AP & BC | BCR-ABL copy number at baseline was not significantly different among I treated patients who ultimately did or did not have cytogenetic response (p=0.09)
Prognostic value of transcript trends while on imatinib treatment | Branford, 2003^33^ (quality = 5/6) CP-new Diagnosis | Among I-treated pts (n=28), median log reduction is associated with MMR at 24 mo; - Med log reduction > 2 versus < 2 at 3mo (100% vs. 54%; p<0.001 by K-M); - Med log reduction > 2 versus < 2 at 6 mo (86% vs. 0%; p<0.001 by K-M) and incidence of progression; - Med log reduction <2 versus > 2 at 6 mo (56% vs 4% p=0.002 by K-M)
Prognostic value of transcript trends while on imatinib treatment | Hughes 2003 (quality = 6/6)11 CP- new diagnosis | Relationship between >3 log reduction@ 12 mo & being progression free @ 24 mo: ≥3 log reduction @ 12 mo: 100% <3 log reduction: 95% no CCR: 85% p=<0.001 Relationship between >3 log reduction and CCR: >3 log reduction at 6 months: I-treated in CCR: 42% IFN+cytarabine in CCR: 13% p=0.03 >3 log reduction at 12 months: I-treated in CCR: 57% IFN+cytarabine in CCR: 24% p=0.003
Prognostic value of transcript trends while on imatinib treatment | Rosti, 2004^8^ (quality 4/5) CP-IFN-r | Median transcript level in pt who reached CCR in <6 mo after start of I: Baseline 0.2330 3 mo 0.0039 6 mo 0.0003 12 mo 0.0005 24 mo 0.0001 Median transcript level in pt who reached CCR in 9–12 mo after start of I: Baseline 0.2490 3 mo 0.0213 6 mo 0.0046 12 mo 0.0034 24 mo 0.0002
Prognostic value of transcript trends while on imatinib treatment | Müller, 2003^104^ (quality 5/6) CP-new Diagnosis | After 3 mo, CCR within the first year could be predicted using the ratio BCR-ABL/ABL (p=0.0026) or BCR-ABL/G6PD (p=0.0074). Empirically derived statistical cutoff point for best prediction of CCR after 12 mo was a ratio BCR-ABL/ABL of 10% at 3 months with a positive predictive value of 71% and a negative predictive value of 82% Empirically derived statistical cutoff point for best prediction of CCR after 12 mo was a reduction of the ratio BCR-ABL/G6PD of 0.3 log after 3 mo with a positive predictive value of 76% and a negative predictive value of 80%, respectively
Prognostic value of transcript trends while on imatinib treatment | *Müller, 2004^106^ (quality *) CP, AP & BC | BCR-ABL/ABL ratios after 12mo were lower in I pts in CCR than I pts with subsequent relapse (0.18–0.60%, p=0.04) In n=132 pt from the IRIS study, no pt with BCR-ABL/ABL <0.12% (>3 log reduction) after 12 mo relapsed
Prognostic value of transcript trends while on imatinib treatment | *Branford, 2004^32^ (quality *) CP | BCR-ABL levels do not appear to decrease substantially after 24 mo on I (see efficacy table, IRIS trial)
Prognostic value of transcript trends while on imatinib treatment | *Cortes, Talpaz, OBrien, Giles, et al., 2004^5^ (quality *) CP-new diagnosis | Relationship between 1 log reduction in transcript levels after 3 mo and 3 log reduction at 24 mo: >1 log: 90% < 1 log: 55% p=0.0002
Prognostic value of transcript trends while on imatinib treatment | *Press, 2004^107^ (quality *) CP | Relationship between >2 log reduction in transcripts at time of CCR and relapse over 29 mo median f/u ≥2 log reduction–3/10 (10%) relapsed <2 log reduction–22/49 (45%) relapsed OR 7.1 (CI 1.9–26)
Prognostic value of transcript trends while on imatinib treatment | Wang, 2003^48^ (quality 2/5) All phases and relapse states including after allogeneic SCT | Relationship to PFS at 500 days estimated from K-M: BCR-ABL/ABL ratio @ 4 wk <50% – 100% BCR-ABL/ABL ratio @ 4 wk >50% – 45% p=0.01 BCR-ABL/ABL ratio @ 3 mo <10% – 100% BCR-ABL/ABL ratio @ 3 mo >10% – 38% p=0.003
Prognostic value of transcript trends while on imatinib treatment | Wu, 2002^6^ (quality 3/5) CP, AP & BC Merx, 2002^105^ (quality = 5/5) CP-IFN-r | BCR-ABL copy number at 3mos was significantly reduced among I treated patients who had a cytogenetic response (p=0.02) and this trend increased with time (p=0.04 at 6 mo, p=0.005 at 9 mo, and p=0.0008 at 12 mo) Median BCR-ABL/ABL ratio at start of I (n=120) was 67% (0.01–100%) Median for CR pts (n=50): 0.85% (0.018–21%) Median for PR pts (n=42): 6.7% (0.5–94%) Median for Minor R pts (n=33): 45% (6–100%) Median for NR pts (n=50): 46% (6–100%) CR to PR (p < 0.0001) PR and MinorR (p < 0.0001), MinorR and NR (p NS) Probability of MCR after 6 mo was higher when ratio <20% at 2 mo (p=0.007)

Abbreviations: *= abstract; AP = Accelerated phase; BP = Blastic phase; CI = 95% confidence interval; CML = Chronic myelogenous leukemia; CP = chronic phase; CR = cytogenetic response; CCR = complete cytogenetic response; f/u = follow-up; I = Imatinib; IFN = Interferon; K-M = Kaplan-Meier; M = Male; MMR = major molecular response; NR = no response; NS = not significant; OR = Odds ratio; OS = Overall Survival; PCR = polymerase chain reaction; PFS = progression-free survival; PR = partial response; pt(s)=patient(s); RR = relative risk; SCT = Stem cell transplant

### Molecular predictors: Group 3–Interaction between the tyrosine kinase protein and imatinib

Mutations in the tyrosine kinase protein have been an active area of inquiry. Only three studies met the eligibility requirements for this review and were therefore included on Table 14.^55, 108, 145^ These studies were of lower quality than the majority of included articles, mainly because they were basic science reports with minor clinical correlations. Since they focused on the basic science, there was less attention in the manuscript to the traditional quality reporting items that are usually considered during secondary clinical research summaries. Further, several studies did not meet the explicit criteria for this review and therefore were highlighted within the “future directions” studies only (Table 1d, “Mechanism of action”). These studies were excluded primarily because they did not clearly provide quantitative assessment of the correlation between the molecular findings and response to imatinib. Taken together, the group of studies presented in Tables 1d and 14 suggest that there is substantial current research effort focusing on the molecular mechanisms of imatinib resistance at the protein level. Some of this work focuses on the gene expression corresponding to imatinib resistance, such as the MRP-1 studies described previously. Others evaluate the relationship between mutations in the tyrosine kinase domain that lead to changes in the protein which might confer imatinib resistance.[Shah, 2002 #292; Hochhaus, 2002 #285; Soverini, 2004 #858] Of particular interest are mutations in the p-loop of the protein where ATP binds and the protein pocket where imatinib binds.112, 114–116 These data are in development; clear evidence of the clinical utility of such information for predicting tumor response and overall survival with imatinib is not available yet.

White and colleagues described an in vitro assay to predict imatinib’s ability to inhibit phosphorylation of the adaptor protein Crkl.145 Crk1 binds BCR-ABL directly and plays a functional role in BCR-ABL-mediated transformation to cancerous CML cells by linking the kinase signal to downstream effector pathways.146 Previous in vitro studies have shown that Crkl phosphorylation correlated with untreated disease and relapse after imatinib, while lack of phosphorylation correlated with response to imatinib.146 White et al.. measured in vitro levels of Crkl phosphorylation of the patients CML cells in the setting of imatinib; using a scoring system of high and low levels of Crkl phosphorylation measured by the IC50, they correlated the IC50 to Major MR. Among newly diagnosed CP CML patients, low IC50 at diagnosis correlated with ability to achieve a Major MR at 12 months. This correlation was particularly strong for those patients with low Sokal scores.

In summary, protein factors related to the interaction between the tyrosine kinase protein and imatinib that can be monitored during therapy and that predict better tumor response include the following:

▪ In vitro evidence of imatinib’s ability to reduce Crkl phosphorylation.

Table 14 Tumor characteristics predictive of disease response or survival: Group 3–Interaction between the tyrosine kinase protein and imatinib

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response
Mutations in tyrosine kinase domain (may lead to I resistance) | Hochhaus, 2002^55^ (quality = 3/6) CP, AP & BC | Median time to relapse: Mutation present (35%)=237 days Mutation not present (65%)= 251 days p=NS
Mutations in tyrosine kinase domain (may lead to I resistance) | Shah, 2002^108^ (quality 1/6) CP & AP | 3/4 pt with CP CML with CHR on I and with kinase domain mutations progressed, whereas 1/9 without mutations progressed
Adapter protein phosphorylation | *White, 2004^145^ (quality *) CML-unclear phase-newly diagnosed | In vitro assay to predict imatinib inhibition of adaptor protein Crkl phosphorylation (measured by IC50). Relationship between IC50, Sokal score and Probability of achieving a MMR at 12mos: All (N=57 newly diagnosed CP CML patients prior to I): Low IC50: MMR = 47% High IC50: MMR = 23% p=0.034 Low Sokal (N=19): Low IC50: MMR = 67% High IC50: MMR = 20% p=0.037 Intermed Sokal (N=15): Low IC50: MMR = 50% High IC50: MMR = 22% p=NS Intermed Sokal (N=16): Low IC50: MMR = 17% High IC50: MMR = 0% p=NS

Abbreviations: *= abstract; AP = Accelerated phase; BC = Blast crisis; CML = Chronic myelogenous leukemia; CP = chronic phase; CHR = complete hematological response; I = Imatinib; MMR = major molecular response; minor = minor response; NS = not significant

### Molecular predictors: Group 4—Other factors

Several other molecular studies are presented in Table 15. Bone marrow cellularity decreases when CML responds to imatinib, an expected finding.109 Myelosuppression due to imatinib of > Grade 3 predicts poorer Major MR rates with imatinib, and if the myelosuppression persists for > 2 weeks the chance of Major MR is even lower.110

The concept of “cure” and complete disease eradication in CML is murky. Even when patients are in CCR, evidence of CML can be found. Bhatia and colleagues showed that all of the 15 patients in Complete CR studied had evidence of BCR-ABL in their CD34+ cells as identified by FISH or RT-PCR up to 61 months after starting imatinib.27 O’Dwyer reported similar findings for seven patients in Major CR.35 Using sensitive RT-PCR techniques Paschka et al. found evidence of BCR-ABL in all samples of CCR patients on imatinib.10 Taken together, these data support the notion that complete remission in CML may be conversion to a low grade chronic disease with continuous potential for relapse over the long term. Using the previous definition from the transplantation literature that “cure” is continued Complete CR at 5 years,13, 34 “cure” may be a relative state of disease control rather than complete eradication.

In summary, other factors monitored during therapy that predict poorer tumor response include the following:

▪ Myelosuppression due to imatinib of greater than Grade 2,
▪ Myelosuppression persisting for more than two weeks.

Table 15 Tumor characteristics predictive of disease response or survival: Group 4—Other factors

Prognostic factor | Studies indicating an association and quality | Strength of association with tumor response | Strength of association with survival
Bone marrow cellularity | Frater, 2003^109^ (quality = 1/5) CP-IFN-r | BM cellularity 100% N =13 with decrease when responds to I
Myelosuppression | Sneed, 2003^110^ (quality 5/6) CP-IFN-r | Any myelosuppression ≥Grade 3: Yes (N=76) MCR 62% CCR 45% No (N=67) MCR 78% CCR 64% P=0.01 Any myelosuppression ≥Grade 3 for > 2wk duration: Yes (N=50) MCR 58% CCR 36% No (N=93) MCR 75% CCR 63% P=0.001
Persistent BCR-ABL in CD34+ cells after CCR with I | Bhatia et al., 2003^27^ (quality = 2/5) CP & AP | 100% (N=15) had persistent evidence of BCR-ABL by FISH or RT-PCR up to 61 months (range 1–61) after starting I
Evidence of BCR-ABL in CCR | Paschka, 2003^10^ (quality = 4/6) CP, AP & BC | 21/68 (31%) samples derived from pts in CCR by conventional cytogenetics have evidence of residual disease by HM-FISH All (N=234) samples of CCR patients had evidence of BCR-ABL by RT-PCR
Abnormal cytogenetics in Ph-cells | O’Dwyer, 2003^35^ (quality 2/5) CP-IFN-r | Clones with abnormal cytogenetics could be identified in the Ph- cells of 7 patients in MCR; link to disease outcome not presented

Abbreviations: AP = Accelerated Phase; BC = Blast crisis; CP = Chronic Phase; CCR = complete cytogenetic response; I = Imatinib; MCR = Major cytogenetic response, Ph- = Philadelphia chromosome negative; pt(s) = patient(s)