# Quality Criteria

## Quality criteria for assessment of experimental studies

1. Was the assignment to the treatment groups random?
  - Adequate approaches to sequence generation
  - - Computer-generated random numbers
  - - Random numbers tables
  - Inadequate approaches to sequence generation
  - - Use of alternation, case record numbers, birth dates or weekdays
2. Was the treatment allocation concealed?
  - Adequate approaches to concealment of randomization
  - - Centralized or pharmacy-controlled randomization
  - - Serially-numbered identical containers
  - - On-site computer based system with a randomization sequence that is not readable until allocation
  - - Other approaches with robust methods to prevent foreknowledge of the allocation sequence to clinicians and patients
  - Inadequate approaches to concealment of randomization
  - - Use of alternation, case record numbers, birth dates or weekdays
  - - Open random numbers lists
  - - Serially numbered envelopes (even sealed opaque envelopes can be subject to manipulation)
3. Were the groups similar at baseline in terms of important prognostic factors?
4. Were the eligibility criteria specified?
5. Were outcome assessors blinded to the treatment allocation?
6. Was the care provider blinded?
7. Was the patient blinded?
8. Were the point estimates and measure of variability presented for the primary outcome measure?
9. Did the analyses include an intention to treat analysis?

## Quality criteria for assessment of observational studies

From the York CRD handbook (http://www.york.ac.uk/inst/crd/crd4_ph5.pdf)

## Cohort studies

Is there a sufficient description of the groups and the distribution of prognostic factor?

Are the groups assembled at a similar point in their disease progression?

Is the intervention/treatment reliably ascertained?

Were the groups comparable on all-important confounding factors?

Was there adequate adjustment for the effects of these confounding variables?

Was a dose-response relationship between intervention and outcome demonstrated?

Was outcome assessment blind to exposure status?

Was follow-up long enough for the outcomes to occur?

What proportion of the cohort was followed-up?

Were dropout rates and reasons for dropout similar across intervention and unexposed groups?

## Case-control studies

Is the case definition explicit?

Had the disease state of the cases been reliably assessed and validated?

Were the controls randomly selected from the source of population of the cases?

How comparable are the cases and controls with respect to potential confounding factors?

Were interventions and other exposures assessed in the same way for cases and controls?

How was the response rate defined?

Were the non-response rates and reasons for non-response the same in both groups?

Is it possible that over-matching has occurred in that cases and controls were matched on factors related to exposure?

Was an appropriate statistical analysis used (matched or unmatched)?

## Case series

Is the study based on a representative sample selected from a relevant population?

Are the criteria for inclusion explicit?

Did all individuals enter the survey at a similar point in their disease progression?

Was follow-up long enough for important events to occur?

Were outcomes assessed using objective criteria or was blinding used?

If comparisons of sub-series are being made, was there a sufficient description of the series and the distribution of prognostic factors?

Appendix B. Table 16 Quality of included studies

Quality Question 1. Is the study based on a representative sample from a relevant population?

Quality Question 2. Are the criteria for inclusion explicit?

Quality Question 3. Did all individuals enter the survey at a similar point in disease progression?

Quality Question 4. Was follow up long enough for important events to occur?

Quality Question 5. Were outcomes assessed using objective criteria or was blinding used?

Quality Question 6. If comparisons of sub-series, was there a sufficient description of the series and distribution of prognostic factors?

First Author, Year | Quality 1: | Quality 2: | Quality 3: | Quality 4: | Quality 5: | Quality 6: | Total score
Baccarani, 2004^91^ | Y | Y | Y | N | Y | N/A | 4/5
Bhatia, 2003^27^ | N | Y | N | Unclear | Y | N/A | 2/5
Branford, 2003^33^ | Y | Y | Y | Y | Y | N | 5/6
Braziel, 2002^67^ | N | Y | Unclear | Y | Y | N | 3/6
Cervantes, 2003^37^ | N | Y | N | N | Y | Y | 3/6
Cohen, 2002^82^ | Y | Y | Y | Unclear | Y | Y | 5/6
Cortes, Giles, et al., 2003^69^ | Y | Y | Unclear | N | Y | N/A | 3/5
Cortes, Talpaz, et al., 2003^1^ | Y | Y | Y | Y | Y | Y | 6/6
Druker, Sawyers, et al., 2001^89^ | Y | Y | Y | N | Y | Y | 5/6
Druker, Talpaz, et al., 2001^66^
Drummond, 2003^92^ | Y | N | Unclear | Unclear | Y | N/A | 2/5
El-Zimaity, 2004^97^ | N | N | N | Y | Y | Y | 3/6
Fischer, 2002^77^ | N | N | N | N | Y | N | 1/6
Frater, 2003^109^ | Unclear | N | Unclear | Unclear | Y | N/A | 1/5
Gardembas, 2003^38^ | Y | Y | Y | Y | Y | N/A | 5/5
Hahn, 2003 (2 full-text articles)60, 61 | Y | Y | Y | Y | Y | N/A | 5/5
Hochhaus, 2002^55^ | Unclear | N | Unclear | Y | Y | Y | 3/6
Hughes, 2003^11^ | Y | Y | Y | Y | Y | Y | 6/6
Huntly, 2003^51^ | Unclear | N | N | N | Y | Y | 2/6
Kantarjian, Sawyers, et al.,2002^2^ | Y | Y | Y | Y | Y | Y | 6/6
Karntarjian, Talpaz, et al., 2002^70^ | Y | Y | Y | Y | Y | N/A | 5/5
Karntarjian, Talpaz, et al., 2003^71^ | N | Y | N | Y | Y | N | 3/6
Karntarjian, Talpaz, et al., 2004^12^ | Y | Y | Y | Y | Y | N/A | 5/5
Kantarjian, Cortes, et al., 2002^90^ | Y | Y | Y | Y | Y | N | 5/6
Karntarjian, Cortes, et al., 2003^63^ | Y | N | Y | N | Y | Y | 6/6
Karntarjian, Cortes, et al., 2004^72^ | N | Y | Y | Y | Y | Y | 5/6
Kantarjian, O’Brien, et al., 2002^78^ | N | Y | N | Y | Y | N | 3/6
Kantarjian, O’Brien, et al., 2003^98^ | N | N | Y | Y | Y | N | 3/6
Kantarjian, O’Brien, et al., 2004^44^ | N | Y | Y | Y | Y | Y | 5/6
Kvasnicka, 2004^111^ | N | N | N | Y | Y | N | 2/6
Lahaye, 2005^75^ | Y | Y | Y | Y | Y | N | 5/6
Lange, 2003^102^ | Y | N | Y | Y | Y | N | 4/6
Le Coutre, 2003^73^ | Y | Y | Y | N | Y | N/A | 4/5
Marin, Goldman, et al., 2003^74^ | Unclear | N | Unclear | N | Y | N/A | 1/5
Marin, Marktel, Bua, et al., 2003^75^ | Y | N | N | Unclear | Y | N/A | 2/5
Marin, Marktel, Szydlo, et al., 2003^75^ | Y | Y | Y | Y | Y | N/A | 5/5
Marktel, 2003^99^ | Y | Y | Y | Y | Y | N | 5/6
McLean103 | Y | Y | Y | Y | Y | N | 5/6
Merx, 2002^105^ | Y | Y | Y | Y | Y | N/A | 5/5
Moravcova, 2004^9^ | N | N | Y | Y | Y | N | 3/6
Müller, 2003^104^ | Y | Y | Y | Y | Y | N | 5/6
O’Brien, Giles, et al., 2003^79^ | N | Y | N | Y | Y | N/A | 3/5
O’Brien, Guilhot, et al., 2003 59 | Y | Y | Y | Y | Y | N/A | 5/5
O’Dwyer, 2003^35^ | N | Y | Unclear | Unclear | Y | N/A | 2/5
O’Dwyer, 2004^96^ | N | N | Unclear | Y | Y | N/A | 2/5
Olavarria, 2003^84^ | Y | Y | N | Y | Y | N | 4/6
Paschka, 2003^10^ | Y | Y | Unclear | Y | Y | Unclear | 4/6
Rosti, 2004^8^ | Unclear | Y | Y | Y | Y | N/A | 4/5
Sawyers, 2002^3^ | Y | Y | Y | Unclear | Y | Y | 5/6
Shah, 2002^108^ | N | N | N | N | Y | N | 1/6
Shimoni, 2003^117^ | N | Y | N | Y | Y | N/A | 3/5
O’Sneed, 2003^110^ | Y | Y | Y | Y | Y | N | 5/6
Soverini, 2004^126^ | N | N | Y | Y | Y | N/A | 3/5
Steegman, 2003^93^ | N | Y | Y | Y | Y | N/A | 4/5
Stentoft, 2001^7^ | N | Y | Y | Y | Y | N/A | 4/5
Sureda, 2003^4^ | Y | Y | Y | Unclear | Y | N/A | 4/5
Talpaz, 2002^87^ | Y | Y | Y | Unclear | Y | Y | 5/6
Valeyrie, 2003^94^ | Y | Y | Y | Unclear | N | N/A | 3/5
Wang, 2003^48^ | N | N | N | Y | Y | N/A | 2/5
Wu, 2002^6^ | N | N | Y | Y | Y | N/A | 3/5

Abbreviations: N = No; Y = Yes; N/A = not applicable