# Executive Summary

Chronic myeloid leukemia (CML) is a malignant clonal disorder of blood cells resulting from the cancerous transformation of a very primitive hematopoietic stem cell. CML’s hallmark is the chromosome 9;22 translocation that produces the BCR-ABL gene, which is present in more than 95 percent of all cases of CML. Imatinib (Gleevec®) is an orally administered drug that competitively inhibits the BCR-ABL tyrosine kinase, a cellular enzyme that is encoded in the BCR-ABL gene. Imatinib works by blocking, or turning off, the signal from the tyrosine kinase protein, so that cancerous cells stop growing. Imatinib is approved by the Food and Drug Administration (FDA) for patients in the first-line and relapsed settings of all phases of CML.

There are three clinical phases of CML–chronic phase (CP), accelerated phase (AP), and blastic phase/blast crisis (BP)–distinguished by their prognoses and clinical presentation. Therapeutic options include imatinib, interferon-alpha with or without cytarabine, hydroxyurea, busulfan, other conventional chemotherapies, and stem cell transplantation (bone marrow transplantation, SCT). Allogeneic SCT is the only curative treatment for CML, however it is only available for 20–25 percent of patients predominantly due to lack of a suitable donor; 15–30 percent treatment-related mortality can be expected with SCT.

This assessment of imatinib for treatment of CML was performed at the request of the Centers for Medicare and Medicaid Services (CMS) and is designed to inform the likely health outcomes associated with a current demonstration project which provides for payment for certain oral medications, including imatinib for CML, that are prescribed as replacements for other drugs currently covered under Medicare Part B.

## Scope and Key Questions

The key questions for this review were developed with experts in the field of oncology, health economics, and health policy. The key questions are as follows:

1. In patients with chronic myeloid leukemia, what is the effect of imatinib compared to interferon alpha or best supportive care on overall survival, disease free survival, remission rates (PR, CHR, cytogenetic remission), and quality of life (QOL)?
2. In patients with chronic myeloid leukemia, what is the effect of imatinib compared to interferon alpha or best supportive care on adverse effects, tolerability, and compliance with treatment?
3. What patient or tumor characteristics distinguish treatment responders from non-responders and have potential to be used to target therapy? In addressing this question, we will focus on the following: (1) predictive patient or tumor characteristics that are related to the mechanism of action of the drug (i.e., molecular target; performance status, while a powerful predictor of outcome, is not related to mechanism of action); (2) candidates for diagnostic testing (even if not commercially or clinically available currently (e.g., PCR)); and, (3) patient or tumor characteristics that are associated with clinically important differences in treatment response.

## Methods

### Search Strategy

Primary studies were sought in a computerized bibliographic search of MEDLINE (1966 through September 2004, updated July 2005) and limited to articles published in the English language. Additional strategies included searching ancillary bibliographic databases, searching abstracts presented at the ASCO and ASH professional meetings since 2004, querying experts, and checking references of included studies and review articles.

### Selection Criteria

Each citation identified from the search strategies was evaluated according to the following selection criteria. Evaluations were performed by the authors.

Inclusion criteria were as follows:

Patients | Patients with CML–any phase
Interventions | Imatinib (Gleevec™ or Glivec™ or [STI571])
Comparators | Any

Study designs:

- For efficacy questions: Prospective clinical trials; may be phase II uncontrolled, or phase III randomized controlled trials.
- For studies of adverse effects: May be retrospective or prospective case series, cohort studies, or clinical trials provided the number of patients treated (at risk for adverse effects) as well as the number with adverse effects can be ascertained.
- For studies of predictors of response: May be retrospective or prospective case series, cohort studies, case-control studies, or clinical trials provided the response can be ascertained for patients with and without the predictor.

Outcomes:

For efficacy questions: Survival, disease-free survival, and quality of life (QOL). In addition to these clinical outcomes, the following intermediate outcomes are assessed.

○ Complete hematologic remission—Normal complete blood count and normal physical examination
○ Complete cytogenetic remission—Normal chromosome examination with no Phpositive cells detectable on metaphase cytogenetic of bone marrow with 20–25 cells analyzed
○ Molecular remission—Negative RT-PCR evidence of the BCR-ABL mRNA

Use of these outcomes can be justified based on their correlation with survival. Cytogenetic response is an independent prognostic factor for improved survival, and has been the therapeutic goal of many trials. An understanding of the relationship between molecular response and survival is developing, but in general molecular response—and specifically early molecular response—correlates with survival

- For studies of adverse effects: Adverse effects, tolerability, and compliance with treatment.
- For studies of predictors of response: Predictive value of patient or tumor characteristics that are associated with clinically important differences in treatment response that are:
  1. related to the mechanism of action of the drug (i.e., molecular target); and
  2. candidates for diagnostic testing (even if not commercially or clinically available currently [e.g., RT-PCR]).

## The Evidence

### Question 1: In patients with chronic myeloid leukemia, what is the effect of imatinib compared to interferon alpha or best supportive care on overall survival, disease free survival, remission rates (PR, CHR, cytogenetic remission (CR)), and quality of life (QOL)

The most compelling evidence for the efficacy of imatinib is the IRIS trial, an international multi-center phase III trial of imatinib vs. interferon plus cytarabine as initial therapy for newly diagnosed chronic phase CML. In the IRIS study, imatinib was clearly superior to interferon plus cytarabine in terms of cytogenetic response (CR; 74 percent vs. 9 percent), molecular response (42 percent vs. 13 percent of those with Complete CR at 6 months), progression free survival (PFS; 92 percent vs. 74 percent at 18 months), and QOL (TOI 84.4 vs. 67.7). Estimates of overall survival (OS) were not significantly different between imatinib and interferon plus cytarabine in the original IRIS publication. Since 58 percent of participants on the interferon plus cytarabine arm crossed over to imatinib in this trial, estimates of OS for the individual groups were difficult. In a followup report on the IRIS trial, the 30-month OS for imatinib was 95 percent. This compares favorably to the previously reported 36-month OS rates for interferon plus cytarabine of 86 percent in the Guilhot study. QOL was studied as part of the IRIS trial, and patients receiving imatinib had significantly better total QOL, social/family well-being, and emotional well-being. Pasquini el al. reported similar findings in a phase II trial conducted in Brazil.

There were some criticisms of the IRIS trial. Most notably, the overall mean dose intensity on the interferon plus cytarabine arm was only 58 percent of the target dose, with the dose intensity of the imatinib arm 97 percent of target. This compares similarly to the Guilhot et al. trial of interferon vs. interferon plus cytarabine where only 57 percent achieved the target dose intensity with interferon. The Baccarini study reported higher rates of achieving target dose intensity with interferon (70 percent), but did not report different survival rates than those seen with the Guilhot et al. trial. The other main criticism of the IRIS trial is that PFS was calculated using loss of CHR, loss of Major CR, or increases in WBC as criteria for progression. This criticism is reflective of the variability in definition of disease progression in CML. For this reason, comparison of more uniform endpoints across trials such as Complete CR or OS may be a more objective measure of relative efficacy.

Efficacy is clearly different by phase of disease and timing within the treatment algorithm, as reflected in Figure 6. Earlier phases and patients treated in the first-line setting had the highest response rates. CP patients treated earlier in the course (i.e., <1 year from diagnosis) had better response rates with imatinib than those treated later in the CP period. In the post-interferon setting, the reason that the interferon was discontinued influenced response rates. Regardless, significant Complete CR rates are seen with imatinib in all treatment settings, including patients who are heavily pre-treated with myelotoxic chemotherapy with or without SCT. The response rates for the heavily pre-treated CP patients are similar to those of the interferon-refractory or intolerant CP patients. The historic control group for the interferon-refractory or intolerant CP patients likely reflects the same or better response rates than would an appropriate control group for the heavily pre-treated CP patients; this group has been used for the comparator group in the heavily-pretreated CP setting.

The AP and BP studies do not report comparator groups, however previous studies suggest that fewer than 5 percent of AP patients achieve a Major CR with interferon. The Complete CR rate for AP treated with interferon can therefore be expected to be lower than 5 percent, and BP lower yet. Studies identified in this review reported Complete CR rates with imatinib of 11–19 percent for AP and 0–10 percent for BP (Figure 6). One year survival rates of 74 percent (95 percent CI 68–81 percent) for AP patients treated with imatinib compare favorably to the historic 6–18 month median life expectancy described in Figure 2. Similarly, the median OS of 6.5–7 months for BP patients treated with imatinib is longer than the historic prognosis of 3–6 months.

### Question 2: In patients with chronic myeloid leukemia, what is the effect of imatinib compared to interferon alpha or best supportive care on adverse effects, tolerability, and compliance with treatment?

Imatinib has far fewer adverse effects (any grade and grade 3/4) compared with interferon. The most reliable data on common adverse effects comes from the IRIS trial in which imatinib most commonly caused neutropenia (61 percent), thrombocytopenia (57 percent), superficial edema (56 percent), nausea (44 percent), and abnormal liver function results (43 percent). Interferon plus cytarabine most commonly caused thrombocytopenia (79 percent), abnormal liver function results (74 percent), neutropenia (67 percent), fatigue (66 percent), nausea (61 percent), anemia (55 percent), and headache (43 percent). The incidence of grade 3/4 side effects was primarily hematological with imatinib (neutropenia 14 percent and thrombocytopenia 8 percent) whereas interferon plus cytarabine included fatigue (24 percent) and hematological (neutropenia 25 percent and thrombocytopenia 17 percent). The incidence of side effects increased with imatinib dose and phase of illness, with hematologic side effects particularly increasing with advancing phases of illness.

Compliance with imatinib was not formally presented in the studies reviewed. Discussions with authors revealed that there is a forthcoming report investigating adherence to imatinib therapy using prescription data for a total of 4043 imatinib-treated patients tracked over 14 months.

Overall, the compliance rate was approximately 75 percent, and persistent continuation on therapy averaged 256 days of therapy over 12 months. Suboptimal adherence to imatinib therapy may be an under-recognized problem that requires active monitoring by healthcare professionals.

### Question 3: What patient or tumor characteristics distinguish treatment responders from non-responders and have potential to be used to target therapy? In addressing this question, we will focus on the following: (1) predictive patient or tumor characteristics that are related to the mechanism of action of the drug (i.e., molecular target; performance status, while a powerful predictor of outcome, is not related to mechanism of action); (2) candidates for diagnostic testing (even if not commercially or clinically available currently (e.g., PCR)); and, (3) patient or tumor characteristics that are associated with clinically important differences in treatment response

#### Molecular predictors: Group 1A--DNA factors at the start of imatinib therapy

DNA factors at the start of imatinib therapy that predict [underlined: poorer] tumor response and/or survival include the following:

▪ 90–100% of metaphases are Ph+ at the start of imatinib;

There were significantly more patients with a Major CR when <90 percent of metaphases were Ph+ at the start of therapy;1, 2 a similar trend for survival was seen, but not statistically significant.

▪ Clonal evolution in AP or BP;

Cytogenetic abnormalities have been investigated both at the time of initial diagnosis and with clinical disease progression (e.g., from chronic to accelerated phase). The language that various authors use to describe this process is imprecise, including descriptions of “other chromosomal abnormalities,” “complex cytogenetics,” and “cytogenetic clonal evolution.” Overall, the most common terminology in “clonal evolution” and therefore this grouping will be used to represent this category of predictive markers. Clonal evolution at the time of initial diagnosis may be a marker for more advanced or aggressive disease. Indeed, larger studies of patients in AP and BP supported that clonal evolution at baseline predicted poorer survival (p<0.005)3, 4 and likely predicted disease progression (p=0.086)

▪ Clonal evolution in CP (predicts risk of relapse and poorer survival);

Ten studies including patients in CP and CP-IFN-r considered cytogenetic clonal evolution as a predictor of tumor response, although it was likely that these studies reflected multiple presentations of the same patient populations. Taken together these studies suggested that cytogenetic clonal evolution inconsistently predicted disease response but was a major predictor of the risk of disease relapse (relative risks (RR) reported 4.34, 4.912, and 14.8) and survival.

▪ Higher percentage of CD34+ cells in the bone marrow; two abstracts that indicated that the percent of CD34+ cells in the bone marrow in CML correlated with tumor response
- Chromosome 9 deletions

Deletions of the resultant DNA on chromosome 9 can be seen in up to 15 percent of cases of CML. Chromosome 9 deletions are known to negatively affect prognosis, decreasing survival by up to 20% at 5 years. These studies were conducted predominantly in patients on interferon-based therapies. In the setting of imatinib, chromosome 9 deletions lead to poorer PFS in CP, AP and BP settings (p=0.02). Overall survival is not significantly different with a median follow up of 48 months.

▪ Genetic profiles

A number of genes are known to be related to drug resistance and programmed cell death (apoptosis) in leukemic cells. Evaluation of gene expression suggested that MRP-1 was overexpressed in blast crisis CML, and that MRP-1 overexpression was significantly correlated with poor tumor response to imatinib. Using gene microarray techniques, McLean and colleagues identified a genomic profile and microarray pattern characteristic of tumor response in CP CML. Patients whose CML met this ideal microarray profile had a substantially greater likelihood of Complete CR (odd ratio (OR) 200, 95 percent CI 19-3096) and Major CR (OR 19.9, 95 percent CI 6-67).

#### Molecular predictors: Group 1B-DNA factors monitored during imatinib therapy

DNA factors monitored during therapy that predict [underlined: better] tumor response and/or survival include the following:

▪ Cytogenetic response; and,

Cytogenetic response (CR) is the most commonly used surrogate marker of tumor response for CML. Its relationship to PFS and OS in the setting of imatinib therapy has been confirmed by at least 7 studies involving all phases of CML. Timing of the CR is also important. Across the analyses that evaluated the time course of the CR, CR by 3 or 6 months strongly predicted PFS and OS. In the only study that compared timepoints, partial CR by 6 months was most predictive of survival

▪ Degree of reduction of CD34+ cells in the bone marrow.

The degree of reduction in CD34+ cells in the bone marrow can be considered another surrogate marker of tumor response. Marin demonstrated that the degree of reduction of CD34+ cells in CML in the setting of imatinib treatment correlated with progression free survival (RR 0.88, 95 percent CI 0.53–0.93). This is consistent with imatinib decreasing the percentage of blasts and normalization to a CHR.

#### Molecular predictors: Group 2–Production of the RNA message

Response to imatinib is independent of BCR-ABL mRNA transcript number at the start of treatment; however, molecular monitoring during imatinib therapy is predictive of overall tumor response.

Factors related to production of the RNA message that are monitored during therapy and predict [underlined: better] tumor response include the following:

▪ Molecular response;

Nine studies support the association between MR and overall tumor response.5–12 An individual patient’s best MR predicts survival and those with very low levels of residual disease (median ratio <0.1 percent) have the more durable Complete CRs. Among all patients in the IRIS study who achieved a Complete CR, those who received imatinib had a greater MR than those who received interferon plus cytarabine (p=0.036).

▪ > 2 log reduction in BCR-ABL mRNA transcripts at 3 or 6 months;
▪ ≥ 3 log reduction in BCR-ABL mRNA transcripts at 12 months; and,
▪ BCR-ABL/ABL ratio <50 percent at 4 weeks.

#### Molecular predictors: Group 3–Interaction between the tyrosine kinase protein and imatinib

There is substantial current research effort focusing on mutations in tyrosine kinase that correspond to imatinib resistance. Of particular interest are mutations in the p-loop of the protein where ATP binds and the protein pocket where imatinib binds. These data are in development; clear evidence of the clinical utility of such information for predicting tumor response and overall survival with imatinib is not available yet.

#### Molecular predictors: Group 4-Other factors

Several other molecular studies point to other factors monitored during therapy that predict [underlined: poorer] tumor response.

▪ Myelosuppression due to imatinib of greater than Grade 2,
▪; Myelosuppression persisting for more than two weeks.

## Discussion

Imatinib has been shown to have activity in all phases of CML, including interferon-refractory CML and CML which has recurred after a stem cell transplant. However, no long-term data exist as yet in regard to the durability of response, and there only emerging data about the efficacy of salvage strategies using interferon alfa or allogeneic stem cell transplantation after disease progression on imatinib.

## Current State of Clinical Use

According to the National Comprehensive Cancer Network (NCCN) guidelines, imatinib is the standard of care as first-line therapy for CP CML when patients are not eligible for SCT. This recommendation of imatinib as first-line therapy is stronger than the previous NCCN guideline which presented imatinib and interferon-based therapy as more equal options. When patients are eligible for SCT, the choice of first-line therapy with imatinib or transplant is still under debate.

The recommended starting dose is 400 mg. The NCCN guideline recommends that therapy is modified if a CHR is not obtained by 3 months. Modification options include reconsideration of SCT, clinical trials, increasing the imatinib to 600–800 mg, or interferon with or without cytarabine. For patients who obtained a CHR at 3 months, 6 month evaluation should include cytogenetic analysis. Patients who achieve at least a Minor CR at 6 months should continue at their current dose or increase to 600–800 mg as tolerated. Potential therapy modifications for patients who do not achieve at least a Minor CR by 6 months again include reconsideration of SCT, clinical trials, increasing the imatinib to 600–800 mg, or interferon with or without cytarabine. For patients who achieve at least a Minor CR at 6 months, 12 month evaluation should again include cytogenetic analysis. Those in Complete CR should continue imatinib at the current dose. Those in Major CR should be increased to 600–800 mg as tolerated, and those in Minor or no CR should proceed with therapy modification or continue imatinib with the goal of maintaining hematologic remission only. The option to start patients out at higher doses of imatinib is presented.

The NCCN guideline recommends bone marrow cytogenetic analysis even if FISH or Q-RT-PCR are available, because cytogenetic findings including clonal evolution may indicate the need to consider other treatment strategies (e.g., clinical trial, increased imatinib dose). Management strategies in the setting of chromosome 9 deletions are not discussed nor is the role of molecular monitoring.

According to the National Cancer Institute (NCI) clinical guide at www.cancer.gov, the timing and role of imatinib for newly diagnosed CP CML are not as clear. This review was most recently updated in February 2005. Particular questions raised by the NCI reviewers include the following:

▪ What is the best dose of imatinib and should it be combined with other agents (such as interferon alfa and/or cytarabine)?
▪ What is the role of allogeneic stem cell transplantation for younger, eligible patients, and should it be offered before or after initiation of imatinib?
▪ Will transplantation be more or equally efficacious before or after failure on imatinib?
▪ Will responses on imatinib be durable for many years, or will responses be short-lived and the relapsing disease be more difficult to control?

Both the NCCN and NCI guidelines are less clear about the optimal management of newly diagnosed AP or BP. Patients with newly diagnosed AP may be enrolled in a clinical trial, undergo SCT, be treated with imatinib, or receive interferon-based therapies (interferon-based treatment is not recommended for AP in the NCCN document). Patients with newly diagnosed BP may be enrolled in a clinical trial, undergo SCT, be treated with imatinib, or receive acute leukemia induction chemotherapy regimens (neither guideline recommends interferon). Imatinib is also a consideration in the relapsed or refractory disease settings when it has not previously been used.

When other treatment strategies have not been successful, chemotherapy with hydroxyurea or busulfan, transfusion support, or palliative care remain options for patients.

## Implications for Future Research

Future directions of research on imatinib for CML fall into two main domains:

1. CLINICAL SCIENCES:
  ▪ efficacy of imatinib therapy alone or in combination with other agents
  ▪ better predictors of patients most likely to respond or at risk of poor response
  ▪ better understanding of the relative efficacy across segments of the population including different racial, ethnic and age groups
  ▪ long-term longitudinal follow up of imatinib in the various clinical settings
  ▪ understanding of the ideal timing of SCT
  ▪ meaning of surrogate markers such as molecular response at specific intervals after the initiation of therapy
  ▪ impact of minimal residual disease when patients are in Complete CR
  ▪ treatment algorithms subjected to objective evaluation
  ▪ safe discontinuation of imatinib when there is a good clinical response
  ▪ multiple drug regimens that include imatinib
2. BASIC SCIENCES:
  ▪ refined understanding of imatinib’s mechanism of action (e.g., anti-angiogenic properties)
  ▪ molecular understanding of mechanisms of drug resistance for imatinib and other targeted therapies
  ▪ better ability to predict individuals likely to be resistant to imatinib
  ▪ development of new technologies so that knowledge of genetic profiles and molecular predictors of resistance can be translated into practical clinical tests
  ▪ development of new targeted therapies that incorporate these molecular insights