# Foreword

Preventing smoking and smokeless tobacco use among young people is critical to ending the epidemic of tobacco use. Since the first Surgeon General’s report on youth in 1994, the basis for concern about smoking during adolescence and young adulthood has expanded beyond the immediate health consequences for the young smoker to a deeper understanding of the implications for health across the life span from early use of tobacco. Cigarette smoking remains the leading cause of preventable death in the United States, accounting for approximately 443,000 deaths, or about 1 of every 5 deaths, in the United States each year.

Since 1994, there have been many legal and scientific developments that have curtailed somewhat the tobacco companies’ ability to market to young people. The 1998 Master Settlement Agreement eliminated most cigarette billboard and transit advertising, print advertising directed to underage youth, and limited brand sponsorship. In addition, the Master Settlement Agreement resulted in the release of internal tobacco industry documents that have been analyzed by scientists. Furthermore, during this time, the prices of cigarettes and smokeless tobacco products also increased. These significant developments, among others, resulted in a sharp decrease in tobacco use among adults and youth. However, this progress has stalled in recent years.

More than 80% of adult smokers begin smoking by 18 years of age with 99% of first use by 26 years of age. In addition, adolescent smokeless tobacco users are more likely than nonusers to become adult cigarette smokers. Adolescents and young adults are uniquely susceptible to social and environmental influences to use tobacco, and tobacco companies spend billions of dollars on cigarette and smokeless tobacco marketing. The findings in this report provide evidence that coordinated, high-impact interventions including mass media campaigns, price increases, and community-level changes protecting people from secondhand smoke and norms are effective in reducing the initiation and prevalence of smoking among youth. However, many of these comprehensive tobacco control programs remain underfunded. Now more than ever, it is imperative that we continue investing in tobacco prevention and control. An increase in spending on sustained comprehensive tobacco control programs will result in reductions in youth and adult smoking rates and, ultimately, in health care costs.

Reducing tobacco use is a winnable battle. We have the science and, with additional effort and support for evidence-based, cost-effective strategies that we can implement now, we will improve on our nation’s health and our children’s future.

Thomas R. Frieden, M.D., M.P.H.

Director

Centers for Disease Control and Prevention

and

Administrator

Agency for Toxic Substances and Disease Registry