# Message from Kathleen Sebelius

Secretary of Health and Human Services

Tobacco is the leading cause of preventable and premature death, killing an estimated 443,000 Americans each year. Cigarette smoking costs the nation $96 billion in direct medical costs and $97 billion in lost productivity annually. In addition to the billions in medical costs and lost productivity, tobacco is enacting a heavy toll on young people.

Each day in the United States, over 3,800 young people under 18 years of age smoke their first cigarette, and over 1,000 youth under age 18 become daily cigarette smokers. The vast majority of Americans who begin daily smoking during adolescence are addicted to nicotine by young adulthood. Despite the well-known health risks, youth and adult smoking rates that had been dropping for many years have stalled. When this Administration took office, we decided that if these numbers were not changing, we had to do something. We accelerated our efforts to fight tobacco by helping Americans stop smoking and protecting young people from starting to smoke.

The first step was the historic Family Smoking Prevention and Tobacco Control Act which gives the U.S. Food and Drug Administration the authority to regulate tobacco products to prevent use by minors and reduce the impact on public health. The law includes many vital provisions, including a ban on cigarettes with certain characterizing flavorings such as candy and fruit, restrictions on the sale of single cigarettes and the prohibition of marketing practices aimed at children. The Family Smoking Prevention and Tobacco Control Act also provides for graphic warning labels that make the danger of smoking abundantly clear.

Second, as part of the Recovery Act, the Department of Health and Human Services (HHS) invested $225 million to support tobacco prevention and control efforts in states. These investments were made in communities that have used evidence-based tobacco interventions and will eventually become models for the rest of the country.

The third step was the Affordable Care Act, which provides a new opportunity to transform how our nation addresses tobacco use through the Prevention and Public Health Fund. The law expands access to recommended treatment programs, such as tobacco use cessation, often at no additional cost. For the first time, Medicare and Medicaid will cover tobacco use cessation for all beneficiaries. The health care law also provides support for state 1–800 quitlines and implementation of innovative social media initiatives including text messaging and smart phone applications.

We are using the many tools at our disposal, from regulatory power to state and local investments, to end the tobacco epidemic. In November 2010, HHS announced the Department’s first ever comprehensive tobacco control strategic action plan, titled Ending the Tobacco Epidemic, which will help us bring all of these strategies together to achieve our goals. An important component of our HHS plan focuses on preventing the initiation of tobacco use among young people, through hard-hitting mass media campaigns that will discourage our country’s youth from starting to use tobacco products and motivate current tobacco users to quit. This key strategic action, combined with others in the plan, signify HHS’s commitment to provide a clear roadmap for the future of tobacco prevention and control.

We have come a long way since the days of smoking on airplanes and in college classrooms, but we have a long way to go. We have the responsibility to act and do something to prevent our youth from smoking. The prosperity and health of our nation depend on it.