# Acknowledgments

This report was prepared by the U.S. Department of Health and Human Services under the general direction of the Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health.

Vice Admiral Regina Benjamin, M.D., M.B.A., Surgeon General, U.S. Public Health Service, Office of the Assistant Secretary for Health, Office of the Surgeon General, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Howard K. Koh, M.D., M.P.H, Assistant Secretary for Health, U.S. Department of Health and Human Services, Washington, D.C.

Thomas R. Frieden, M.D., M.P.H., Director, Centers for Disease Control and Prevention, Atlanta, Georgia.

Ursula E. Bauer, Ph.D., M.P.H., Director, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Barbara Bowman, Ph.D., Associate Director for Science, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Tim A. McAfee, M.D., M.P.H., Director, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Terry F. Pechacek, Ph.D., Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

## The editors of the report were

Cheryl L. Perry, Ph.D., Senior Scientific Editor, Professor and Regional Dean, and Rockwell Distinguished Chair in Society and Health, Michael and Susan Dell Center for Healthy Living, School of Public Health, University of Texas, Austin, Texas.

Melissa H. Stigler, Ph.D., M.P.H., Senior Associate Editor, Assistant Professor, Division of Epidemiology, Human Genetics, and Environmental Sciences, Michael and Susan Dell Center for Healthy Living, School of Public Health, University of Texas, Austin, Texas.

Leslie Norman, M.B.A., Managing Editor, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Peter L. Taylor, M.B.A., Technical Editor, Fairfax, Virginia.

## Contributing editors were

Frank J. Chaloupka, Ph.D., Director, Health Policy Center, Institute for Health Research and Policy, University of Illinois, Chicago, Illinois.

Brian R. Flay, D. Phil., Professor, Department of Public Health, Oregon State University, Corvallis, Oregon.

Jonathan M. Samet, M.D., M.S., Professor and Flora L. Thornton Chair, Department of Preventive Medicine, Keck School of Medicine, Director, Institute for Global Health, University of Southern California, Los Angeles, California.

Melissa H. Stigler, Ph.D., M.P.H., Assistant Professor, Division of Epidemiology, Human Genetics, and Environmental Sciences, Michael and Susan Dell Center for Healthy Living, School of Public Health, University of Texas, Austin, Texas.

Steve Sussman, Ph.D., Professor of Preventive Medicine and Psychology, Institute for Prevention Research, Keck School of Medicine, University of Southern California, Los Angeles, California.

## Contributing authors were

Susan L. Ames, Ph.D., Associate Professor, School of Community and Global Health and Psychology, Claremont Graduate University, Claremont, California.

Deborah A. Burnette, Expert Consultant, ICF International, Atlanta, Georgia.

Frank J. Chaloupka, Ph.D., Director, Health Policy Center, Institute for Health Research and Policy, University of Illinois, Chicago, Illinois.

K. Michael Cummings, Ph.D., M.P.H., Senior Research Scientist, Chair, Department of Health Behavior, Division of Cancer Prevention and Population Sciences, Roswell Park Cancer Institute, Buffalo, New York.

Cristine Delnevo, Ph.D., M.P.H., Associate Professor, Director, Center for Tobacco Surveillance and Evaluation Research, University of Medicine and Dentistry of New Jersey, School of Public Health, New Brunswick, New Jersey.

Lori Dorfman, Dr. P.H., M.P.H., Director, Berkeley Media Studies Group, a project of the Public Health Institute, Berkeley, California.

Sarah J. Durkin, Ph.D., Senior Research Fellow, Centre for Behavioral Research in Cancer, Cancer Council Victoria, Melbourne, Australia.

Susan T. Ennett, Ph.D., Professor, Department of Health Behavior and Health Education, Gillings School of Global Public Health, University of North Carolina, Chapel Hill, North Carolina.

Michael Eriksen, Sc.D., Professor and Director, Institute of Public Health, Georgia State University, Atlanta, Georgia.

Ellen Feighery, R.N., M.S., Associate Director, International Research, Campaign for Tobacco-Free Kids, Washington, D.C.

Brian R. Flay, D. Phil., Professor, Department of Public Health, Oregon State University, Corvallis, Oregon.

Geoffrey Fong, Ph.D., Professor, Department of Psychology, University of Waterloo, Waterloo, Ontario, Canada, and Senior Investigator, Ontario Institute for Cancer Research, Toronto, Ontario, Canada.

Jean L. Forster, Ph.D., M.P.H., Professor, Division of Epidemiology and Community Health, School of Public Health, University of Minnesota, Minneapolis, Minnesota.

Samuel S. Gidding, M.D., Professor of Pediatrics, Thomas Jefferson University, Nemours Cardiac Center, A. I. duPont Hospital for Children, Wilmington, Delaware.

Gary A. Giovino, Ph.D., M.S., Professor and Chair, Department of Community Health and Health Behavior, School of Public Health and Health Professions, University at Buffalo, State University of New York, Buffalo, New York.

Stanton Glantz, Ph.D., Professor of Medicine, American Legacy Foundation Distinguished Professor in Tobacco Control, Department of Medicine, Division of Cardiology, University of California, San Francisco, California.

Diane R. Gold, M.D., M.P.H., Channing Laboratory, Brigham and Women’s Hospital, Professor of Medicine, Harvard Medical School, and Associate Professor of Environmental Health, Harvard School of Public Health, Boston, Massachusetts.

Bonnie L. Halpern-Felsher, Ph.D., Professor of Pediatrics, Department of Pediatrics, Division of Adolescent Medicine, University of California, San Francisco, California.

David Hammond, Ph.D., Associate Professor, School of Public Health and Health Systems, University of Waterloo, Waterloo, Ontario, Canada.

Yvonne Hunt, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, U.S. Department of Health and Human Services, Bethesda, Maryland.

Laura Kann, Ph.D., Branch Chief, Surveillance and Evaluation Research Branch, Division of Adolescent and School Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Rachel Kaufmann, Ph.D., M.P.H., Deputy Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Steve Kinchen, Team Leader, Data Management and Analysis Team, Surveillance and Evaluation Research Branch, Division of Adolescent and School Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Robert C. Klesges, Ph.D., Professor, Department of Preventive Medicine, University of Tennessee Health Science Center, and Member, Division of Epidemiology and Cancer Control, St. Jude Children’s Research Hospital, Memphis, Tennessee.

Suchitira Krishnan-Sarin, Ph.D., Associate Professor, Department of Psychiatry, Yale University School of Medicine, New Haven, Connecticut.

Karol Kumpfer, Ph.D., Psychologist, Program Developer and Professor of Health Promotion and Education, Department of Health Promotion and Education, University of Utah, Salt Lake City, Utah.

Genelle Lamont, M.P.H., Doctoral Student, Division of Epidemiology and Community Health, School of Public Health, University of Minnesota, Minneapolis, Minnesota.

Christina N. Lessov-Schlaggar, Ph.D., Research Assistant Professor, Department of Psychiatry, School of Medicine, Washington University, St. Louis, Missouri.

Pamela Ling, M.D., M.P.H., Associate Professor of Medicine, Division of General Internal Medicine, Center for Tobacco Control Research and Education, University of California, San Francisco, California.

Patrick M. O’Malley, Ph.D., Research Professor, Survey Research Center, Institute for Social Research, University of Michigan, Ann Arbor, Michigan.

Terry F. Pechacek, Ph.D., Associate Director for Science, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Cheryl L. Perry, Ph.D., Professor and Regional Dean, and Rockwell Distinguished Chair in Society and Health, Michael and Susan Dell Center for Healthy Living, School of Public Health, University of Texas, Austin, Texas.

Kurt M. Ribisl, Ph.D., Associate Professor, Department of Health Behavior and Health Education, Gillings School of Global Public Health, University of North Carolina, Chapel Hill, North Carolina.

Joni L. Rutter, Ph.D., Acting Director, Division of Basic Neuroscience and Behavioral Research, National Institute on Drug Abuse, National Institutes of Health, U.S. Department of Health and Human Services, Bethesda, Maryland.

Henry Saffer, Ph.D., Research Associate, National Bureau of Economic Research, New York, New York.

Jonathan M. Samet, M.D., M.S., Professor and Flora L. Thornton Chair, Department of Preventive Medicine, Keck School of Medicine, Director, Institute for Global Health, University of Southern California, Los Angeles, California.

James Sargent, M.D., Professor of Pediatrics, Dartmouth Medical School, Co-Director, Cancer Control Research Program, Norris Cotton Cancer Center, Lebanon, New Hampshire.

Herbert H. Severson, Ph.D., Senior Research Scientist, Oregon Research Institute, Eugene, Oregon.

Deborah Sherrill-Mittleman, Ph.D., Clinical Research Scientist, Division of Epidemiology and Cancer Control, St. Jude Children’s Research Hospital, Memphis, Tennessee.

Anna V. Song, Ph.D., Assistant Professor, Health Psychology, School of Social Sciences, Humanities and Arts, Psychological Sciences, University of California, Merced, California.

Melissa H. Stigler, Ph.D., M.P.H., Assistant Professor, Division of Epidemiology, Human Genetics, and Environmental Sciences, Michael and Susan Dell Center for Healthy Living, School of Public Health, University of Texas, Austin, Texas.

Steve Sussman, Ph.D., Professor of Preventive Medicine and Psychology, Institute for Prevention Research, Keck School of Medicine, University of Southern California, Los Angeles, California.

John A. Tauras, Ph.D., Associate Professor, Department of Economics, and Research Associate, National Bureau of Economic Research, University of Illinois, Chicago, Illinois.

Jennifer B. Unger, Ph.D., Professor of Preventive Medicine, Keck School of Medicine, University of Southern California, Alhambra, California.

Mark Vander Weg, Ph.D., Associate Professor, Departments of Psychology and General Internal Medicine, University of Iowa, Iowa City, Iowa.

Melanie Wakefield, Ph.D., Director, Centre for Behavioural Research in Cancer, Cancer Council Victoria, Melbourne, Australia.

Rachel Widome, Ph.D, M.H.S., Core Investigator, Center for Chronic Disease Outcomes Research and Assistant Professor, Department of Medicine, University of Minnesota, Minneapolis, Minnesota.

Phillip W. Wilbur, M.A., Director, Tobacco Control and Health Programs, Danya International Inc., Silver Spring, Maryland.

## Reviewers were

Cathy L. Backinger, Ph.D., M.P.H., Chief, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Stephen W. Banspach, Ph.D., Associate Director for Science, Division of Adolescent and School Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Neal Benowitz, M.D., Professor of Medicine and Bioengineering and Therapeutic Sciences, and Chief, Division of Clinical Pharmacology and Experimental Therapeutics, University of California, San Francisco, California.

Gerald S. Berenson, M.D., Research Professor, Department of Epidemiology, School of Public Health and Tropical Medicine, Tulane Center for Cardiovascular Health, New Orleans, Louisiana.

Stella A. Bialous, R.N., M.Sc.N., Dr. P.H., President, Tobacco Policy International, San Francisco, California.

Lois Biener, Ph.D., Senior Research Fellow, Center for Survey Research, University of Massachusetts, Boston, Massachusetts.

Anthony Biglan, Ph.D., Senior Scientist, Oregon Research Institute, Eugene, Oregon.

Mary Beth Bigley, Dr.P.H., M.S.N., A.N.P., Acting Director of the Office of Science and Communication, Office of the Surgeon General, Office of the Assistant Secretary for Health, Office of the Secretary, U.S. Department of Health and Human Services, Washington, D.C.

Michele Bloch, M.D., Ph.D., Medical Officer, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Alan Blum, M.D., Director, The University of Alabama Center for the Study of Tobacco and Society, Tuscaloosa, Alabama.

David M. Burns, M.D., Professor Emeritus, Department of Family and Preventive Medicine, School of Medicine, University of California, San Diego, California.

Ralph S. Caraballo, Ph.D., M.P.H., Branch Chief, Epidemiology Branch, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Wilson M. Compton, M.D., M.P.E., Director, Division of Epidemiology, Services and Prevention Research, National Institute on Drug Abuse, Bethesda, Maryland.

Gregory N. Connolly, D.M.D., M.P.H., Professor, Department of Society, Human Development, and Health, Harvard School of Public Health, Harvard University, Boston, Massachusetts.

David Cowling, Ph.D., Chief, Evaluation Unit, California Department of Public Health, California Tobacco Control Program, Sacramento, California.

Jennifer Cullen, Ph.D., M.P.H., Director of Epidemiologic Research, Center for Prostate Disease Research, Research Assistant Professor, Department of Surgery, Uniformed Services University of the Health Sciences, Rockville, Maryland.

K. Michael Cummings, Ph.D., M.P.H., Senior Research Scientist, Chair, Department of Health Behavior, Division of Cancer Prevention and Population Sciences, Roswell Park Cancer Institute, Buffalo, New York.

Joseph DiFranza, M.D., Professor, Department of Family Medicine and Community Health, University of Massachusetts Medical School, Worcester, Massachusetts.

Timothy Dewhirst, Ph.D., Associate Professor, Department of Marketing and Consumer Studies, College of Management and Economics, University of Guelph, Guelph, Ontario, Canada.

Shanta R. Dube, Ph.D., M.P.H., Lead Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Sherry L. Emery, Ph.D., Senior Research Scientist, Institute for Health Research and Policy, University of Illinois, Chicago, Illinois.

Michael Eriksen, Sc.D., Professor and Director, Institute of Public Health, Georgia State University, Atlanta, Georgia.

Pebbles Fagan, Ph.D., M.P.H., Associate Professor and Program Director, Prevention and Control Program, University of Hawaii Cancer Center, Honolulu, Hawaii.

Jean L. Forster, Ph.D., M.P.H., Professor, Division of Epidemiology and Community Health, School of Public Health, University of Minnesota, Minneapolis, Minnesota.

Erika Fulmer, M.H.A., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Elizabeth M. Ginexi, Ph.D., Program Director, Tobacco Control Research Branch, Division of Cancer Control and Population Sciences, National Cancer Institute, Bethesda, Maryland.

Stanton Glantz, Ph.D., Professor of Medicine, American Legacy Foundation Distinguished Professor in Tobacco Control, Department of Medicine, Division of Cardiology, University of California, San Francisco, California.

Thomas J. Glynn, Ph.D., Director, Cancer Science and Trends, and Director, International Cancer Control, American Cancer Society, Washington, D.C.

Marvin E. Goldberg, Ph.D., Emeritus Bard Professor of Marketing, Pennsylvania State University, and University Associate, Eller College of Management, University of Arizona, Tucson, Arizona.

Susan Marsiglia Gray, M.P.H., Coordinator, National Synar Program, Substance Abuse and Mental Health Services Administration/Center for Substance Abuse Prevention, Rockville, Maryland.

Gerard Hastings, Ph.D., OBE, Professor, Director, Institute for Social Marketing and Centre for Tobacco Control Research, University of Stirling and the Open University, Stirling, Scotland.

Dorothy Hatsukami, Ph.D., Forster Family Professor in Cancer Prevention, Professor of Psychiatry, Tobacco Research Programs, University of Minnesota, Minneapolis, Minnesota.

Lynne Haverkos, M.D., M.P.H., Program Director, Pediatric Behavior and Health Promotion, Eunice Kennedy Shriver National Institute of Child Health and Human Development, National Institutes of Health, Bethesda, Maryland.

Jack E. Henningfield, Ph.D., Vice President, Research and Health Policy, Pinney Associates, Bethesda, Maryland; and Professor, Adjunct, Department of Psychiatry and Behavioral Sciences, The Johns Hopkins University School of Medicine, Baltimore, Maryland.

Lisa Henriksen, Ph.D., Senior Research Scientist, Stanford Prevention Research Center, Stanford University School of Medicine, Palo Alto, California.

Yvonne M. Hunt, Ph.D., M.P.H., Program Director, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, National Institutes of Health, Bethesda, Maryland.

Corinne Husten, M.D., M.P.H., Senior Medical Advisor, Center for Tobacco Products, Food and Drug Administration, Rockville, Maryland.

Andrew Hyland, Ph.D., Research Scientist, Department of Health Behavior, Division of Cancer Prevention and Population Sciences, Roswell Park Cancer Institute, Buffalo, New York.

Charles Irwin, Jr., M.D., Distinguished Professor of Pediatrics and Director of the Division of Adolescent Medicine, University of California San Francisco, California.

Rachel Kaufmann, Ph.D., M.P.H., Deputy Associate Director for Science, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Steven H. Kelder, M.P.H., Ph.D., Professor, Division of Epidemiology, Human Genetics, and Environmental Sciences, Co-Director, Michael and Susan Dell Center for Healthy Living, University of Texas School of Public Health, Austin, Texas.

Brian A. King, Ph.D., M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Jonathan D. Klein, M.D., M.P.H., Professor of Pediatrics, Department of Pediatrics, University of Rochester School of Medicine and Dentistry, Rochester, New York, Associate Executive Director, and Director, Julius B. Richmond Center, American Academy of Pediatrics, Elk Grove Village, Illinois.

Katherine Kolor, Ph.D., M.S., Health Scientist, Office of Public Health Genomics, Centers for Disease Control and Prevention, Atlanta, Georgia.

Kelli A. Komro, M.P.H., Ph.D., Professor, Department of Health Outcomes and Policy, College of Medicine, Associate Director, Institute for Child Health Policy, University of Florida, Gainesville, Florida.

Nicole M. Kuiper, M.P.H., Health Scientist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

John Kulig, M.D., M.P.H., Director, Adolescent Medicine, Tufts Medical Center, Boston, Massachusetts.

Youn Ok Lee, Ph.D., Postdoctoral Fellow, Center for Tobacco Control Research and Education, University of California, San Francisco, California.

Pamela Ling, M.D, M.P.H., Associate Professor of Medicine, Division of General Internal Medicine, Center for Tobacco Control Research and Education, University of California, San Francisco, California.

Kathryn P. Mayhew, Ph.D., Associate Professor, Counselor Education and Educational Psychology, Saint Cloud State University, Saint Cloud, Minnesota.

Robin J. Mermelstein, Ph.D., Director, Institute for Health Research and Policy, Professor, Psychology Department, Clinical Professor, Community Health Sciences, School of Public Health, Institute for Health Research and Policy, University of Illinois, Chicago, Illinois.

Matthew L. Myers, J.D., President, Campaign for Tobacco-Free Kids, Washington, D.C.

Elizabeth Ozer, Ph.D., Associate Professor, Division of Adolescent Medicine, Department of Pediatrics, University of California, San Francisco, California.

Mark Parascandola, Ph.D., M.P.H., Epidemiologist, Tobacco Control Research Branch, Behavioral Research Program, Division of Cancer Control and Population Sciences, National Cancer Institute, Bethesda, Maryland.

John P. Pierce, Ph.D., Sam M. Walton Professor for Cancer Research, Department of Family and Preventive Medicine, and Associate Director for Population Sciences, Moores Cancer Center, University of California at San Diego, La Jolla, California.

John M. Pinney, President, Pinney Associates, Bethesda, Maryland.

Richard Pollay, Ph.D., Professor Emeritus, Marketing Division, and Curator, History of Advertising Archives, Sauder School of Business, University of British Columbia, Vancouver, British Columbia, Canada.

Gabbi Promoff, M.A., Issues Management Team Lead, Policy Unit, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

William Riley, Ph.D., Program Director, Division of Cardiovascular Sciences, National Heart, Lung, and Blood Institute, Bethesda, Maryland._

Rosemary Rosso, J.D., Senior Attorney, Federal Trade Commission, Washington, D.C.

Joni L. Rutter, Ph.D., Acting Director, Division of Basic Neuroscience and Behavioral Research, National Institute on Drug Abuse, National Institutes of Health, U.S. Department of Health and Human Services, Bethesda, Maryland.

Yussuf Saloojee, Ph.D., Executive Director, National Council Against Smoking, Johannesburg, South Africa.

Dana Shelton, M.P.H., Associate Director for Policy, Planning, and Coordination, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Frank E. Speizer, M.D., Professor of Medicine, Channing Laboratory, Harvard Medical School, Professor of Environmental Science, Department of Environmental Health, Harvard School of Public Health, Harvard University, Boston, Massachusetts.

James F. Thrasher, Ph.D., M.S., M.A., Assistant Professor, Health Promotion, Education, and Behavior, Arnold School of Public Health, University of South Carolina, Columbia, South Carolina, and Visiting Professor and Researcher, Instituto Nacional de Salud Publica, Cuernavaca, Mexico.

Douglas Tipperman, M.S.W., Lead Public Health Advisor, Center for Substance Abuse Prevention, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.

Donna Vallone, Ph.D., M.P.H., Senior Vice President, Research, American Legacy Foundation, Washington, D.C.

Kasisomayajula Viswanath, Ph.D., Associate Professor, Harvard School of Public Health, and Associate Professor of Medical Oncology, Dana-Farber Cancer Institute, Boston, Massachusetts.

Kenneth E. Warner, Ph.D., Avedis Donabedian Distinguished University Professor of Public Health, School of Public Health, University of Michigan, Ann Arbor, Michigan.

Jonathan P. Winickoff, M.D., M.P.H., Associate Professor of Pediatrics, Harvard University Medical School, Massachusetts General Hospital for Children, Boston, Massachusetts.

## Other contributors were

René A. Arrazola, M.P.H., Epidemiologist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

David Chyen, M.S., Survey Statistician, Data Management and Analysis Team, Surveillance and Evaluation Research Branch, Division of Adolescent and School Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

James D. Colliver, Ph.D., Statistician (Retired), Division of Population Surveys, Substance Abuse and Mental Health Services Administration, Rockville, Maryland.

MeLisa R. Creamer, M.P.H., Doctoral Student and Dell Health Scholar, Michael and Susan Dell Center for Healthy Living, University of Texas School of Public Health, Austin, Texas.

Athena Foong, Research Writer/Research Assistant to Jonathan M. Samet, M.D., M.S., Department of Preventive Medicine, Keck School of Medicine, Institute for Global Health, University of Southern California, Los Angeles, California.

Joseph Gfroerer, Director, Division of Population Surveys, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Service Administration, Rockville, Maryland. __

Beth Han, M.D., Ph.D., M.P.H., Statistician, Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Service Administration, Rockville, Maryland. _

William A. Harris, M.M., System Developer, Data Management and Analysis Team, Surveillance and Evaluation Research Branch, Division of Adolescent and School Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Ghada Homsi, M.E., Research Economist, Public Health Policy Research, RTI international, Research Triangle Park, North Carolina.

Lynn A. Hughley, Health Communications Specialist, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Tim McManus, M.S., Survey Statistician, Data Management and Analysis Team, Surveillance and Evaluation Research Branch, Division of Adolescent and School Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Luz M. Moncayo, Executive Assistant to Jonathan M. Samet, M.D., M.S., Department of Preventive Medicine, Keck School of Medicine, Institute for Global Health, University of Southern California, Los Angeles, California.

Emily Neusel, M.P.H., Doctoral Student, Michael and Susan Dell Center for Healthy Living, University of Texas School of Public Health, Austin Regional Campus, Austin, Texas.

Tariq Qureshi, M.D., M.P.H., Data Manager, Data Management and Analysis Team, Surveillance and Evaluation Research Branch, Division of Adolescent and School Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Derek Smolenski, Ph.D., Research Associate, Division of Epidemiology and Community Health, School of Public Health, University of Minnesota, Minneapolis, Minnesota.

Kathryn Szynal, Editorial Assistant, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Angela Trosclair, M.S., Statistician, Office on Smoking and Health, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.

Kimberly M. White, Executive Assistant to the Regional Dean, University of Texas School of Public Health, Austin, Texas.

Peggy Williams, M.S., Technical Writer-Editor, National Center for Chronic Disease Prevention and Health Promotion, Centers for Disease Control and Prevention, Atlanta, Georgia.